# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Adil E. Bharucha, M.B.B.S., M.D.
  Gastroenterology
  Mayo Clinic
  Rochester, MN
- Cheryle B. Gartley
  Consumer Representative/Advocate
  President, The Simon Foundation for Continence
  Chicago, IL
- Debra Hagerty, D.N.P., R.N., NHA, FACDONA
  National Association Directors of Nursing
  Administration in Long Term Care
  Armstrong Atlantic State University
  Savannah, GA
- Tracy L. Hull, M.D.
  Colorectal Surgery
  Cleveland Clinic Foundation
  Cleveland, OH
- Anders Mellgren, M.D., Ph.D., FACS, FASCRS
  American Society of Colon and Rectal Surgeons
  University of Illinois
  Chicago, IL
- Susan M. Miller, M.D.
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Christine Norton, Ph.D., M.A., R.N.
  Nursing
  Kings' College
  London, UK
- Nancy J. Norton
  Consumer Representative/Advocate
  President, International Foundation for Functional Gastrointestinal Disorders
  Milwaukee, WI
- Satish S.C. Rao, M.D., Ph.D.
  American Gastroenterological Association
  Georgia Regents University Medical Center
  Augusta, GA
- Todd H. Rockwood, Ph.D.
  Health Services Research/Outcomes
  University of Minnesota
  Minneapolis, MN
- Rebecca G. Rogers, M.D.
  American College of Obstetrics and Gynecology
  University of New Mexico
  Albuquerque, NM
- Vivian W. Sung, M.D., M.P.H.
  Obstetrics and Gynecology
  Alpert Medical School of Brown University
  Providence, RI
- Maureen White, M.S., M.D., M.B.A.
  Blue Cross Blue Shield of Minnesota
  Eagan, MN