# Acknowledgments

The authors wish to thank Uzoma Abakporo and Victoria Nelson, who served as research assistants on this project, and Marilyn Eells and Jeannine Ouellette for their assistance in editing the report. The authors also wish to thank the former AHRQ Task Order Officers for this project, Nahed El-Kassar and Supriya Janakiraman.