# Conclusions

Only a few nonsurgical treatments for FI in adults had sufficient-quality evidence to inform patient care; the surgical evidence is of insufficient quality for clinical decisionmaking. The use of numerous outcome measures impedes the field. Substantial methodological and reporting issues can be rectified by following current study and reporting standards; small improvements could provide higher quality evidence. The overall strength of evidence for treatments for FI in adults was low or insufficient, suggesting that future studies with higher quality could change the conclusions of this review.