# References

1 Browning GG, Parks AG. Postanal repair for neuropathic faecal incontinence: correlation of clinical result and anal canal pressures. Br J Surg. Feb. 1983;70(2):101-4. [pmid: 6824891].
2 Jorge JM, Wexner SD. Etiology and management of fecal incontinence. Dis Colon Rectum. Jan. 1993;36(1):77-97. [pmid: 8416784].
3 Bols EM, Hendriks HJ, Berghmans LC, et al. Responsiveness and interpretability of incontinence severity scores and FIQL in patients with fecal incontinence: a secondary analysis from a randomized controlled trial. International Urogynecology Journal. Mar. 2013;24(3):469-78. [pmid: 22806487].
4 Bharucha AE, Locke GR 3rd, Seide BM, et al. A new questionnaire for constipation and faecal incontinence. Aliment Pharmacol Ther. Aug. 1. 2004;20(3):355-64. [pmid: 15274673].
5 Rockwood TH, Church JM, Fleshman JW, et al. Patient and surgeon ranking of the severity of symptoms associated with fecal incontinence: the fecal incontinence severity index. Dis Colon Rectum. Dec. 1999;42(12):1525-32. [pmid: 10613469].
6 Jelovsek JE, Chen Z, Markland AD, et al. Minimum Important Differences for Scales Assessing Symptom Severity and Quality of Life in Patients with Fecal Incontinence. Female Pelvic Med Reconstr Surg. 2014. Sep. 1. [pmid: 25185630].
7 Miller R, Bartolo DC, Locke-Edmunds JC, et al. Prospective study of conservative and operative treatment for faecal incontinence. British Journal of Surgery. Feb. 1988;75(2):101-5. [pmid: 3349291].
8 Pescatori M, Anastasio G, Bottini C, et al. New grading and scoring for anal incontinence. Evaluation of 335 patients. Diseases of the Colon & Rectum. May. 1992;35(5):482-7. [pmid: 1568401].
9 Lunniss PJ, Kamm MA, Phillips RK. Factors affecting continence after surgery for anal fistula. British Journal of Surgery. Sep. 1994;81(9):1382-5. [pmid: 7953425].
10 Vaizey CJ, Carapeti E, Cahill JA, et al. Prospective comparison of faecal incontinence grading systems. Gut. Jan. 1999;44(1):77-80. [pmid: 9862829].
11 Bols EM, Hendriks EJ, Deutekom M, et al. Inconclusive psychometric properties of the Vaizey score in fecally incontinent patients: a prospective cohort study. Neurourology & Urodynamics. Mar. 2010;29(3):370-7. [pmid: 19634170].
12 Wong WD, Congliosi SM, Spencer MP, et al. The safety and efficacy of the artificial bowel sphincter for fecal incontinence: results from a multicenter cohort study. Diseases of the Colon & Rectum. Sep. 2002;45(9):1139-53. [pmid: 12352228].
13 Rockwood TH, Church JM, Fleshman JW, et al. Fecal Incontinence Quality of Life Scale: quality of life instrument for patients with fecal incontinence. Diseases of the Colon & Rectum. Jan. 2000;43(1):9-16. discussion -7. [pmid: 10813117].
14 Hallgren T, Fasth S, Delbro DS, et al. Loperamide improves anal sphincter function and continence after restorative proctocolectomy. Digestive Diseases & Sciences. Dec. 1994;39(12):2612-8. [pmid: 7995187].
15 Heymen S, Scarlett Y, Jones K, et al. Randomized controlled trial shows biofeedback to be superior to pelvic floor exercises for fecal incontinence. Diseases of the Colon & Rectum. Oct. 2009;52(10):1730-7. [pmid: 19966605].
16 Schnelle JF, Alessi CA, Simmons SF, et al. Translating clinical research into practice: a randomized controlled trial of exercise and incontinence care with nursing home residents. Journal of the American Geriatrics Society. Sep. 2002;50(9):1476-83. [pmid: 12383143].
17 Schnelle JF, Leung FW, Rao SS, et al. A controlled trial of an intervention to improve urinary and fecal incontinence and constipation. Journal of the American Geriatrics Society. Aug. 2010;58(8):1504-11. [pmid: 20653804].
18 Christensen P, Bazzocchi G, Coggrave M, et al. A randomized, controlled trial of transanal irrigation versus conservative bowel management in spinal cord-injured patients. Gastroenterology. Sep. 2006;131(3):738-47. [pmid: 16952543].
19 Schwandner T, Hemmelmann C, Heimerl T, et al. Triple-target treatment versus low-frequency electrostimulation for anal incontinence: a randomized, controlled trial. Deutsches Arzteblatt International. Sep. 2011;108(39):653-60. [pmid: 22013492].
20 Bliss DZ, Jung HJ, Savik K, et al. Supplementation with dietary fiber improves fecal incontinence. Nursing Research. Jul-Aug. 2001;50(4):203-13. [pmid: 11480529].
21 Yoshioka K, Ogunbiyi OA, Keighley MR. A pilot study of total pelvic floor repair or gluteus maximus transposition for postobstetric neuropathic fecal incontinence. Diseases of the Colon & Rectum. Feb. 1999;42(2):252-7. [pmid: 10211504].
22 Palmer KR, Corbett CL, Holdsworth CD. Double-blind cross-over study comparing loperamide, codeine and diphenoxylate in the treatment of chronic diarrhea. Gastroenterology. Dec. 1980;79(6):1272-5. [pmid: 7002706].
23 Duelund-Jakobsen J, Dudding T, Bradshaw E, et al. Randomized double-blind crossover study of alternative stimulator settings in sacral nerve stimulation for faecal incontinence. British Journal of Surgery. Oct. 2012;99(10):1445-52. [pmid: 22961528].
24 Michelsen HB, Krogh K, Buntzen S, et al. A prospective, randomized study: switch off the sacral nerve stimulator during the night?. Diseases of the Colon & Rectum. May. 2008;51(5):538-40. [pmid: 18299927].
25 Kusunoki M, Shoji Y, Ikeuchi H, et al. Usefulness of valproate sodium for treatment of incontinence after ileoanal anastomosis. Surgery. Mar. 1990;107(3):311-5. [pmid: 2106731].
26 Bartlett L, Sloots K, Nowak M, et al. Biofeedback for fecal incontinence: a randomized study comparing exercise regimens. Diseases of the Colon & Rectum. Jul. 2011;54(7):846-56. [pmid: 21654252].
27 Sun WM, Read NW, Verlinden M. Effects of loperamide oxide on gastrointestinal transit time and anorectal function in patients with chronic diarrhoea and faecal incontinence. Scandinavian Journal of Gastroenterology. Jan. 1997;32(1):34-8. [pmid: 9018764].
28 Leroi AM, Parc Y, Lehur PA, et al. Efficacy of sacral nerve stimulation for fecal incontinence: results of a multicenter double-blind crossover study. Annals of Surgery. Nov. 2005;242(5):662-9. [pmid: 16244539].
29 Osterberg A, Edebol Eeg-Olofsson K, Hallden M, et al. Randomized clinical trial comparing conservative and surgical treatment of neurogenic faecal incontinence. British Journal of Surgery. Sep. 2004;91(9):1131-7. [pmid: 15449263].
30 Read M, Read NW, Barber DC, et al. Effects of loperamide on anal sphincter function in patients complaining of chronic diarrhea with fecal incontinence and urgency. Digestive Diseases & Sciences. Sep. 1982;27(9):807-14. [pmid: 7105952].
31 Duelund-Jakobsen J, Buntzen S, Lundby L, et al. Sacral nerve stimulation at subsensory threshold does not compromise treatment efficacy: results from a randomized, blinded crossover study. Annals of Surgery. Feb. 2013;257(2):219-23. [pmid: 23001079].
32 Norton C, Chelvanayagam S. Methodology of biofeedback for adults with fecal incontinence: a program of care. J Wound Ostomy Continence Nurs. May. 2001;28(3):156-68. [pmid: 11337702].
33 Norton C, Chelvanayagam S, Wilson-Barnett J, et al. Randomized controlled trial of biofeedback for fecal incontinence. Gastroenterology. Nov. 2003;125(5):1320-9. [pmid: 14598248].
34 van Tets WF, Kuijpers JH. Pelvic floor procedures produce no consistent changes in anatomy or physiology. Diseases of the Colon & Rectum. Mar. 1998;41(3):365-9. [pmid: 9514434].
35 Agachan F, Chen T, Pfeifer J, et al. A constipation scoring system to simplify evaluation and management of constipated patients. Dis Colon Rectum. Jun. 1996;39(6):681-5. [pmid: 8646957].
36 Thin NN, Taylor SJ, Bremner SA, et al. Randomized clinical trial of sacral versus percutaneous tibial nerve stimulation in patients with faecal incontinence. Br J Surg. Mar. 2015;102(4):349-58. [pmid: 25644291].
37 Damon H, Siproudhis L, Faucheron JL, et al. Perineal retraining improves conservative treatment for faecal incontinence: A multicentre randomized study. Digestive and Liver Disease. March. 2014;46(3):237-42. [pmid: 24444704].
38 Morris OJ, Smith S, Draganic B. Comparison of bulking agents in the treatment of fecal incontinence: a prospective randomized clinical trial. Techniques in Coloproctology. Oct. 2013;17(5):517-23. [pmid: 23525964].
39 Pinedo G, Zarate AJ, Inostroza G, et al. New treatment for faecal incontinence using zinc-aluminium ointment: a double-blind randomized trial. Colorectal Disease. May. 2012;14(5):596-8. [pmid: 21781231].
40 Graf W, Mellgren A, Matzel KE, et al. Efficacy of dextranomer in stabilised hyaluronic acid for treatment of faecal incontinence: a randomised, sham-controlled trial. Lancet. Mar. 19. 2011;377(9770):997-1003. [pmid: 21420555].
41 Schwandner T, Konig IR, Heimerl T, et al. Triple target treatment (3T) is more effective than biofeedback alone for anal incontinence: the 3T-AI study. [Erratum appears in Dis Colon Rectum. 2011 Nov;54(11):1461]. Diseases of the Colon & Rectum. Jul. 2010;53(7):1007-16. [pmid: 20551752].
42 Pinedo G, Garcia E, Zarate AJ, et al. Are topical oestrogens useful in faecal incontinence? Double-blind randomized trial. Colorectal Disease. May. 2009;11(4):390-3. [pmid: 18637100].
43 Tjandra JJ, Chan MK, Yeh HC. Injectable silicone biomaterial (PTQ) is more effective than carbon-coated beads (Durasphere) in treating passive faecal incontinence--a randomized trial. Colorectal Disease. May. 2009;11(4):382-9. [pmid: 18637935].
44 Tjandra JJ, Chan MK, Yeh CH, et al. Sacral nerve stimulation is more effective than optimal medical therapy for severe fecal incontinence: a randomized, controlled study. Diseases of the Colon & Rectum. May. 2008;51(5):494-502. [pmid: 18278532].
45 Naimy N, Lindam AT, Bakka A, et al. Biofeedback vs. electrostimulation in the treatment of postdelivery anal incontinence: a randomized, clinical trial. Diseases of the Colon & Rectum. Dec. 2007;50(12):2040-6. [pmid: 17914654].
46 Healy CF, Brannigan AE, Connolly EM, et al. The effects of low-frequency endo-anal electrical stimulation on faecal incontinence: a prospective study. International Journal of Colorectal Disease. Dec. 2006;21(8):802-6. [pmid: 16544149].
47 Davis KJ, Kumar D, Poloniecki J. Adjuvant biofeedback following anal sphincter repair: a randomized study. Alimentary Pharmacology & Therapeutics. Sep. 1. 2004;20(5):539-49. [pmid: 15339325].
48 Mahony RT, Malone PA, Nalty J, et al. Randomized clinical trial of intra-anal electromyographic biofeedback physiotherapy with intra-anal electromyographic biofeedback augmented with electrical stimulation of the anal sphincter in the early treatment of postpartum fecal incontinence. American Journal of Obstetrics & Gynecology. Sep. 2004;191(3):885-90. [pmid: 15467559].
49 O'Brien PE, Dixon JB, Skinner S, et al. A prospective, randomized, controlled clinical trial of placement of the artificial bowel sphincter (Acticon Neosphincter) for the control of fecal incontinence. Diseases of the Colon & Rectum. Nov. 2004;47(11):1852-60. [pmid: 15622577].
50 Hasegawa H, Yoshioka K, Keighley MR. Randomized trial of fecal diversion for sphincter repair. Diseases of the Colon & Rectum. Jul. 2000;43(7):961-4. discussion 4-5. [pmid: 10910243].
51 Deen KI, Oya M, Ortiz J, et al. Randomized trial comparing three forms of pelvic floor repair for neuropathic faecal incontinence. British Journal of Surgery. Jun. 1993;80(6):794-8. [pmid: 8330179].
52 Coggrave MJ, Norton C. The need for manual evacuation and oral laxatives in the management of neurogenic bowel dysfunction after spinal cord injury: a randomized controlled trial of a stepwise protocol. Spinal Cord. Jun. 2010;48(6):504-10. [pmid: 19949417].
53 Bharucha AE, Fletcher JG, Camilleri M, et al. Effects of clonidine in women with fecal incontinence. Clinical Gastroenterology and Hepatology. May. 2014;12(5):843-51.e2. [pmid: 23891925].
54 Bliss DZ, Savik K, Jung HJ, et al. Dietary fiber supplementation for fecal incontinence: a randomized clinical trial. Res Nurs Health. Oct. 2014;37(5):367-78. [pmid: 25155992].
55 Ilnyckyj A, Fachnie E, Tougas G. A randomized-controlled trial comparing an educational intervention alone vs education and biofeedback in the management of faecal incontinence in women. Neurogastroenterology & Motility. Feb. 2005;17(1):58-63. [pmid: 15670265].
56 Whitehead WE, Burgio KL, Engel BT. Biofeedback treatment of fecal incontinence in geriatric patients. Journal of the American Geriatrics Society. May. 1985;33(5):320-4. [pmid: 3989196].
57 Lauti M, Scott D, Thompson-Fawcett MW. Fibre supplementation in addition to loperamide for faecal incontinence in adults: a randomized trial. Colorectal Disease. Jul. 2008;10(6):553-62. [pmid: 18190615].
58 Park JS, Kang SB, Kim DW, et al. The efficacy and adverse effects of topical phenylephrine for anal incontinence after low anterior resection in patients with rectal cancer. International Journal of Colorectal Disease. Nov. 2007;22(11):1319-24. [pmid: 17569063].
59 Solomon MJ, Pager CK, Rex J, et al. Randomized, controlled trial of biofeedback with anal manometry, transanal ultrasound, or pelvic floor retraining with digital guidance alone in the treatment of mild to moderate fecal incontinence. Diseases of the Colon & Rectum. Jun. 2003;46(6):703-10. [pmid: 12794569].
60 Krogh K, Nielsen J, Djurhuus JC, et al. Colorectal function in patients with spinal cord lesions. Diseases of the Colon and Rectum. 1997;40(10):1233-9. [pmid: 9336119].
61 Fynes MM, Marshall K, Cassidy M, et al. A prospective, randomized study comparing the effect of augmented biofeedback with sensory biofeedback alone on fecal incontinence after obstetric trauma. Diseases of the Colon & Rectum. Jun. 1999;42(6):753-8. discussion 8-61. [pmid: 10378599].
62 Carapeti EA, Kamm MA, Nicholls RJ, et al. Randomized, controlled trial of topical phenylephrine for fecal incontinence in patients after ileoanal pouch construction. Diseases of the Colon & Rectum. Aug. 2000;43(8):1059-63. [pmid: 10950003].
63 Norton C, Gibbs A, Kamm MA. Randomized, controlled trial of anal electrical stimulation for fecal incontinence. Diseases of the Colon & Rectum. Feb. 2006;49(2):190-6. [pmid: 16362803].
64 Carapeti EA, Kamm MA, Phillips RK. Randomized controlled trial of topical phenylephrine in the treatment of faecal incontinence. British Journal of Surgery. Jan. 2000;87(1):38-42. [pmid: 10606908].
65 Dehli T, Stordahl A, Vatten LJ, et al. Sphincter training or anal injections of dextranomer for treatment of anal incontinence: a randomized trial. Scandinavian Journal of Gastroenterology. Mar. 2013;48(3):302-10. [pmid: 23298304].
66 Bols E, Berghmans B, de Bie R, et al. Rectal balloon training as add-on therapy to pelvic floor muscle training in adults with fecal incontinence: a randomized controlled trial. Neurourology & Urodynamics. Jan. 2012;31(1):132-8. [pmid: 22038680].
67 Ware JE Jr., Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. Jun. 1992;30(6):473-83. [pmid: 1593914].
68 Sze EH, Hobbs G. Efficacy of methylcellulose and loperamide in managing fecal incontinence. Acta Obstetricia et Gynecologica Scandinavica. 2009;88(7):766-71. [pmid: 19452328].
69 Remes-Troche JM, Ozturk R, Philips C, et al. Cholestyramine--a useful adjunct for the treatment of patients with fecal incontinence. International Journal of Colorectal Disease. Feb. 2008;23(2):189-94. [pmid: 17938939].
70 Byrne CM, Solomon MJ, Rex J, et al. Telephone vs. face-to-face biofeedback for fecal incontinence: comparison of two techniques in 239 patients. Diseases of the Colon & Rectum. Dec. 2005;48(12):2281-8. [pmid: 16258709].
71 Loening-Baucke V. Efficacy of biofeedback training in improving faecal incontinence and anorectal physiologic function. Gut. Dec. 1990;31(12):1395-402. [pmid: 2265781].
72 van der Hagen SJ, van der Meer W, Soeters PB, et al. A prospective non-randomized two-centre study of patients with passive faecal incontinence after birth trauma and patients with soiling after anal surgery, treated by elastomer implants versus rectal irrigation. International Journal of Colorectal Disease. Sep. 2012;27(9):1191-8. [pmid: 22576903].
73 Hong KD, da Silva G, Wexner SD. What is the best option for failed sphincter repair?. Colorectal Disease. April. 2014;16(4):298-303. [pmid: 24617736].
74 Wong MT, Meurette G, Wyart V, et al. Does the magnetic anal sphincter device compare favourably with sacral nerve stimulation in the management of faecal incontinence?. Colorectal Disease. Jun. 2012;14(6):e323-9. [pmid: 22339789].
75 Wong MT, Meurette G, Stangherlin P, et al. The magnetic anal sphincter versus the artificial bowel sphincter: a comparison of 2 treatments for fecal incontinence. Diseases of the Colon & Rectum. Jul. 2011;54(7):773-9. [pmid: 21654242].
76 Ratto C, Litta F, Parello A, et al. Sacral nerve stimulation is a valid approach in fecal incontinence due to sphincter lesions when compared to sphincter repair. Diseases of the Colon & Rectum. Mar. 2010;53(3):264-72. [pmid: 20173471].
77 Dudding TC, Pares D, Vaizey CJ, et al. Comparison of clinical outcome between open and percutaneous lead insertion for permanent sacral nerve neurostimulation for the treatment of fecal incontinence. Diseases of the Colon & Rectum. Mar. 2009;52(3):463-8. [pmid: 19333047].
78 Steele SR, Lee P, Mullenix PS, et al. Is there a role for concomitant pelvic floor repair in patients with sphincter defects in the treatment of fecal incontinence?. International Journal of Colorectal Disease. Sep. 2006;21(6):508-14. [pmid: 16075237].
79 Tan M, O'Hanlon DM, Cassidy M, et al. Advantages of a posterior fourchette incision in anal sphincter repair. Diseases of the Colon & Rectum. Nov. 2001;44(11):1624-9. [pmid: 11711734].
80 Osterberg A, Edebol Eeg-Olofsson K, Graf W. Results of surgical treatment for faecal incontinence. British Journal of Surgery. Nov. 2000;87(11):1546-52. [pmid: 11091244].
81 Briel JW, de Boer LM, Hop WC, et al. Clinical outcome of anterior overlapping external anal sphincter repair with internal anal sphincter imbrication. Diseases of the Colon & Rectum. Feb. 1998;41(2):209-14. [pmid: 9556246].
82 Bliss DZ, Savik K, Jung HJ, et al. Symptoms associated with dietary fiber supplementation over time in individuals with fecal incontinence. Nursing Research. May-Jun. 2011;60(3 Suppl):S58-67. [pmid: 21543963].
83 Abbas MA, Tam MS, Chun LJ. Radiofrequency treatment for fecal incontinence: is it effective long-term?. Diseases of the Colon & Rectum. May. 2012;55(5):605-10. [pmid: 22513440].
84 Ruiz D, Pinto RA, Hull TL, et al. Does the radiofrequency procedure for fecal incontinence improve quality of life and incontinence at 1-year follow-up?. Diseases of the Colon & Rectum. Jul. 2010;53(7):1041-6. [pmid: 20551757].
85 Takahashi-Monroy T, Morales M, Garcia-Osogobio S, et al. SECCA procedure for the treatment of fecal incontinence: results of five-year follow-up. Diseases of the Colon & Rectum. Mar. 2008;51(3):355-9. [pmid: 18204954].
86 Lefebure B, Tuech JJ, Bridoux V, et al. Temperature-controlled radio frequency energy delivery (Secca procedure) for the treatment of fecal incontinence: results of a prospective study. International Journal of Colorectal Disease. Oct. 2008;23(10):993-7. [pmid: 18594840].
87 Felt-Bersma RJ, Szojda MM, Mulder CJ. Temperature-controlled radiofrequency energy (SECCA) to the anal canal for the treatment of faecal incontinence offers moderate improvement. European Journal of Gastroenterology & Hepatology. Jul. 2007;19(7):575-80. [pmid: 17556904].
88 Efron JE, Corman ML, Fleshman J, et al. Safety and effectiveness of temperature-controlled radio-frequency energy delivery to the anal canal (Secca procedure) for the treatment of fecal incontinence. Diseases of the Colon & Rectum. Dec. 2003;46(12):1606-16. discussion 16-8. [pmid: 14668584].
89 Chereau N, Lefevre JH, Shields C, et al. Antegrade colonic enema for faecal incontinence in adults: long-term results of 75 patients. Colorectal Disease. Aug. 2011;13(8):e238-42. [pmid: 21689331].
90 Worsoe J, Christensen P, Krogh K, et al. Long-term results of antegrade colonic enema in adult patients: assessment of functional results. Diseases of the Colon & Rectum. Oct. 2008;51(10):1523-8. [pmid: 18622642].
91 Koivusalo AI, Pakarinen MP, Pauniaho SL, et al. Antegrade continence enema in the treatment of congenital fecal incontinence beyond childhood. Diseases of the Colon & Rectum. Nov. 2008;51(11):1605-10. [pmid: 18629588].
92 Krogh K, Laurberg S. Malone antegrade continence enema for faecal incontinence and constipation in adults. British Journal of Surgery. Jul. 1998;85(7):974-7. [pmid: 9692576].
93 Oom DM, Gosselink MP, Schouten WR. Anterior sphincteroplasty for fecal incontinence: a single center experience in the era of sacral neuromodulation. Diseases of the Colon & Rectum. Oct. 2009;52(10):1681-7. [pmid: 19966598].
94 Kaiser AM. Cloaca-like deformity with faecal incontinence after severe obstetric injury--technique and functional outcome of ano-vaginal and perineal reconstruction with X-flaps and sphincteroplasty. Colorectal Disease. Oct. 2008;10(8):827-32. [pmid: 18205849].
95 Grey BR, Sheldon RR, Telford KJ, et al. Anterior anal sphincter repair can be of long term benefit: a 12-year case cohort from a single surgeon. BMC Surgery. 2007;7:1. [pmid: 17217528].
96 Ha HT, Fleshman JW, Smith M, et al. Manometric squeeze pressure difference parallels functional outcome after overlapping sphincter reconstruction. Diseases of the Colon & Rectum. May. 2001;44(5):655-60. [pmid: 11357023].
97 Ho YK, Tan M, Seow-Choen F. Anterior anal sphincter repair for faecal incontinence: Anorectal manometric and endoanal ultrasound assessment. Asian Journal of Surgery. 1999;22(1):89-92.
98 Sitzler PJ, Thomson JP. Overlap repair of damaged anal sphincter. A single surgeon's series. Diseases of the Colon & Rectum. Dec. 1996;39(12):1356-60. [pmid: 8969660].
99 Nikiteas N, Korsgen S, Kumar D, et al. Audit of sphincter repair. Factors associated with poor outcome. Diseases of the Colon & Rectum. Oct. 1996;39(10):1164-70. [pmid: 8831535].
100 Gibbs DH, Hooks VH 3rd. Overlapping sphincteroplasty for acquired anal incontinence. Southern Medical Journal. Dec. 1993;86(12):1376-80. [pmid: 8272915].
101 Keighley MR. Postanal repair for faecal incontinence. Journal of the Royal Society of Medicine. Apr. 1984;77(4):285-8. [pmid: 6716379].
102 Moya P, Arroyo A, Lacueva J, et al. Sacral nerve stimulation in the treatment of severe faecal incontinence: Long-term clinical, manometric and quality of life results. Techniques in Coloproctology. February. 2014;18(2):179-85. [pmid: 23624794].
103 McNevin MS, Moore M, Bax T. Outcomes associated with Interstim therapy for medically refractory fecal incontinence. American Journal of Surgery. May. 2014;207(5):735-7. [pmid: 24791636].
104 Maeda Y, Lundby L, Buntzen S, et al. Outcome of sacral nerve stimulation for fecal incontinence at 5 years. Annals of Surgery. 2014;259(6):1126-31. [pmid: 23817505].
105 Feretis M, Karandikar S, Chapman M. Medium-term results with sacral nerve stimulation for management of faecal incontinence, a single centre experience. Journal of Interventional Gastroenterology. 2013;3(3):82-8.
106 Damon H, Barth X, Roman S, et al. Sacral nerve stimulation for fecal incontinence improves symptoms, quality of life and patients' satisfaction: results of a monocentric series of 119 patients. International Journal of Colorectal Disease. Feb. 2013;28(2):227-33. [pmid: 22885883].
107 Hull T, Giese C, Wexner SD, et al. Long-term durability of sacral nerve stimulation therapy for chronic fecal incontinence. Diseases of the Colon & Rectum. Feb. 2013;56(2):234-45. [pmid: 23303153].
108 Faucheron JL, Chodez M, Boillot B. Neuromodulation for fecal and urinary incontinence: Functional results in 57 consecutive patients from a single institution. Diseases of the Colon and Rectum. December. 2012;55(12):1278-83. [pmid: 23135587].
109 Pascual I, Gomez Cde C, Ortega R, et al. Sacral nerve stimulation for fecal incontinence. Revista Espanola de Enfermedades Digestivas. Jul. 2011;103(7):355-9. [pmid: 21770681].
110 Mellgren A, Wexner SD, Coller JA, et al. Long-term efficacy and safety of sacral nerve stimulation for fecal incontinence. Diseases of the Colon & Rectum. Sep. 2011;54(9):1065-75. [pmid: 21825885].
111 Maeda Y, Lundby L, Buntzen S, et al. Suboptimal outcome following sacral nerve stimulation for faecal incontinence. British Journal of Surgery. Jan. 2011;98(1):140-7. [pmid: 21136568].
112 Wexner SD, Coller JA, Devroede G, et al. Sacral nerve stimulation for fecal incontinence: results of a 120-patient prospective multicenter study. Annals of Surgery. Mar. 2010;251(3):441-9. [pmid: 20160636].
113 Michelsen HB, Thompson-Fawcett M, Lundby L, et al. Six years of experience with sacral nerve stimulation for fecal incontinence. Diseases of the Colon & Rectum. Apr. 2010;53(4):414-21. [pmid: 20305440].
114 Faucheron JL, Voirin D, Badic B. Sacral nerve stimulation for fecal incontinence: causes of surgical revision from a series of 87 consecutive patients operated on in a single institution. Diseases of the Colon & Rectum. Nov. 2010;53(11):1501-7. [pmid: 20940598].
115 El-Gazzaz G, Zutshi M, Salcedo L, et al. Sacral neuromodulation for the treatment of fecal incontinence and urinary incontinence in female patients: long-term follow-up. International Journal of Colorectal Disease. Dec. 2009;24(12):1377-81. [pmid: 19488765].
116 Hetzer FH, Hahnloser D, Clavien PA, et al. Quality of life and morbidity after permanent sacral nerve stimulation for fecal incontinence. Archives of Surgery. 2007;142(1):8-13. [pmid: 17224495].
117 Rasmussen OO, Buntzen S, Sorensen M, et al. Sacral nerve stimulation in fecal incontinence. Diseases of the Colon and Rectum. July. 2004;47(7):1158-62. [pmid: 15216409].
118 Jarrett ME, Varma JS, Duthie GS, et al. Sacral nerve stimulation for faecal incontinence in the UK. British Journal of Surgery. Jun. 2004;91(6):755-61. [pmid: 15164447].
119 Kenefick NJ, Vaizey CJ, Cohen RCG, et al. Medium-term results of permanent sacral nerve stimulation for faecal incontinence. British Journal of Surgery. 2002;89(7):896-901. [pmid: 12081740].
120 Boenicke L, Kim M, Reibetanz J, et al. Stapled transanal rectal resection and sacral nerve stimulation - impact on faecal incontinence and quality of life. Colorectal Disease. Apr. 2012;14(4):480-9. [pmid: 21689328].
121 Hultman CS, Zenn MR, Agarwal T, et al. Restoration of fecal continence after functional gluteoplasty: Long-term results, technical refinements, and donor-site morbidity. Annals of Plastic Surgery. January. 2006;56(1):65-71. [pmid: 16374099].
122 Darnis B, Faucheron JL, Damon H, et al. Technical and functional results of the artificial bowel sphincter for treatment of severe fecal incontinence: is there any benefit for the patient?. Diseases of the Colon & Rectum. Apr. 2013;56(4):505-10. [pmid: 23478619].
123 Wong MT, Meurette G, Wyart V, et al. The artificial bowel sphincter: a single institution experience over a decade. Annals of Surgery. Dec. 2011;254(6):951-6. [pmid: 22107742].
124 Michot F, Lefebure B, Bridoux V, et al. Artificial anal sphincter for severe fecal incontinence implanted by a transvaginal approach: experience with 32 patients treated at one institution. Diseases of the Colon & Rectum. Aug. 2010;53(8):1155-60. [pmid: 20628279].
125 Ruiz Carmona MD, Alos Company R, Roig Vila JV, et al. Long-term results of artificial bowel sphincter for the treatment of severe faecal incontinence. Are they what we hoped for?. Colorectal Disease. Oct. 2009;11(8):831-7. [pmid: 18662237].
126 Melenhorst J, Koch SM, van Gemert WG, et al. The artificial bowel sphincter for faecal incontinence: a single centre study. International Journal of Colorectal Disease. Jan. 2008;23(1):107-11. [pmid: 17929038].
127 Casal E, San Ildefonso A, Carracedo R, et al. Artificial bowel sphincter in severe anal incontinence. Colorectal Disease. May. 2004;6(3):180-4. [pmid: 15109383].
128 Parker SC, Spencer MP, Madoff RD, et al. Artificial bowel sphincter: long-term experience at a single institution. Diseases of the Colon & Rectum. Jun. 2003;46(6):722-9. [pmid: 12794572].
129 Ortiz H, Armendariz P, DeMiguel M, et al. Complications and functional outcome following artificial anal sphincter implantation. British Journal of Surgery. Jul. 2002;89(7):877-81. [pmid: 12081737].
130 Devesa JM, Rey A, Hervas PL, et al. Artificial anal sphincter: complications and functional results of a large personal series. Diseases of the Colon & Rectum. Sep. 2002;45(9):1154-63. [pmid: 12352229].
131 Altomare DF, Dodi G, La Torre F, et al. Multicentre retrospective analysis of the outcome of artificial anal sphincter implantation for severe faecal incontinence. British Journal of Surgery. Nov. 2001;88(11):1481-6. [pmid: 11683745].
132 O'Brien PE, Skinner S. Restoring control: The Acticon Neosphincter artificial bowel sphincter in the treatment of anal incontinence. Diseases of the Colon and Rectum. 2000;43(9):1213-6. [pmid: 11005485].
133 Lehur PA, Roig JV, Duinslaeger M. Artificial anal sphincter: prospective clinical and manometric evaluation. Diseases of the Colon & Rectum. Aug. 2000;43(8):1100-6. [pmid: 10950008].
134 Christiansen J, Rasmussen OO, Lindorff-Larsen K. Long-term results of artificial anal sphincter implantation for severe anal incontinence. Annals of Surgery. Jul. 1999;230(1):45-8. [pmid: 10400035].
135 Wald A, Bharucha AE, Cosman BC, et al. ACG clinical guideline: management of benign anorectal disorders. Am J Gastroenterol. Aug. 2014;109(8):1141-57. (Quiz) 058. [pmid: 25022811].
136 Paquette IM, Madhulika V, Kaiser AM, et al. The American Society of Colon and Rectal Surgeons' Clinical Practice Guideline for the Treatment of Fecal Incontinence. Diseases of the Colon & Rectum. 2015;58(7):623-36. [pmid: 26200676].