# Evidence Tables

Table F1 Patient-reported outcomes used in fecal incontinence randomized controlled trials

Table F2 KQ 1: Fecal incontinence randomized controlled trial outcomes overview by treatment and followup duration

Table F3 KQ 1: Distribution of treatments by FI etiology in randomized controlled trials

Table F4 KQ 1: Surgical treatments for fecal incontinence: randomized controlled trials and quality ratings

Table F5 KQ 1: Observational studies* of fecal incontinence treatments with study quality ratings

Table F6 KQ 2: Adverse effects of nonsurgical treatments for fecal incontinence in randomized controlled trials

Table F7 KQ 2: Adverse effects of treatments for fecal incontinence in observational studies with comparison groups

Table F8 KQ 2: Adverse effects of surgical treatments for fecal incontinence in randomized controlled trials

Table F9 KQ 2: Adverse effects reported in surgical case series of fecal incontinence treatments

Table F10 KQ 1: Benefits of treatment: Summary and strength of evidence of effectiveness and comparative effectiveness of treatments for fecal incontinence in adults by strength of evidence domains*

Table F11 Risk of bias ratings for randomized clinical trials of fecal incontinence treatments

Table F12 Risk of bias in fecal incontinence observational studies with comparison group

Table F13 Recommendations for treatments for fecal incontinence from professional society guidelines compared with MN EPC report findings