# Common Fecal Incontinence Outcome Measures

Table E Common fecal incontinence outcome measures

Measure | Description | Scoring Range/Items | Best Score | Minimal Clinically Important Difference (MID) (if known) | MID method(s)
Severity and impact
Browning and Parks Incontinence Score1 | Degree: 4 categories (A) continent for solid/liquid, B) continent for solid/liquid, not gas, C) continent for solid, not liquid/gas, D) incontinent for solid/liquid/gas) | A-D 4 items | A
Cleveland Clinic Fecal Incontinence Score/Wexner (CCFIS)2 | Frequency: 5 categories (low: <1/month to high: >1/day) Consistency: 3 categories (gas, liquid, solid) Pad use; Lifestyle alteration | 0-20 5 items | 0 | -2 to -3 points3 | Anchor-based
Fecal Incontinence and Continence Assessment (FICA)4 | Frequency (low: ≤1/month to high: ≥2-3/week); Consistency/Amount (gas only/soiling, small amount of stool, moderate/large amount of stool); Pad use; Urgency | 1-12 4 items | 1
Fecal Incontinence Severity Instrument (FISI)5 | Frequency: 6 categories (low: 1-3/month to high:>2/day) Consistency: 4 categories (gas, liquid, solid, mucous) | 0-61 4 items | 0 | -4 points6 | Anchor- and distribution-based
Miller's Incontinence Score7 | Frequency: 3 categories (low: <1/month to high: >1/week) Consistency: 3 categories (gas, liquid, solid) | 0-18 3 items | 0
Pescatori Fecal Incontinence Score8 | Frequency: 3 categories (occasionally, weekly, daily) Consistency: 3 categories (gas, liquid, solid) | 0-6 3 items | 0
St. Mark's Fecal Incontinence Score9 | Frequency: 4 categories (low: <1/month; high: most days); Consistency: 3 categories (gas, liquid, solid); Urgency; Difficulty cleaning; Soiling | 0-13 6 items | 0
Vaizey Fecal Incontinence Score10 | Frequency: 5 categories (low: 1/month; high: every day); Consistency: 3 categories (gas, liquid, solid); Pad use; Urgency; Lifestyle alterations; Antidiarrheal medication use | 0-24 7 items | 0 | -5 points11 -3 to -5 points3 | Anchor- and distribution-based; Anchor-based
Quality of life
American Medical Systems Fecal Incontinence Quality of Life Questionnaire12 | Modification of FIQL13 Physical impact, Psychological impact, Social impact, Pad use, Lifestyle alterations, Embarrassment/shame, Depression, Coping/Behavior | NR 39 items | NR
Fecal Incontinence Quality of Life (FIQL) Scale13 | 4 scales (items): Lifestyle (10), Coping/Behavior (9), Depression/Self-Perception (7), Embarrassment (3) [Measure provides subscale scores (not overall)] | 1-5 per item 29 items | 5 (NA) | 1.1 to 1.2 points3 per subscale | Anchor-based

Best score= least impaired score possible in scale.

CCFIS=Cleveland Clinic Florida Fecal Incontinence Score; FI=Fecal Incontinence; FIQL=Fecal Incontinence Quality of Life; FISI=Fecal Incontinence Severity Score; GPE=Global Perceived Effect; ICIQ-BS=International Consultation Incontinence Questionnaire Bowel Symptoms; NA=not applicable; NR=not reported; SF-36=Short Form Health Survey