# Risk of Bias Assessment Forms

FI Randomized Controlled Trials

FI Observational Studies