# Excluded Studies

## Not a Direct FI Treatment Study (n = 22)

1 Elsebae MM. A study of fecal incontinence in patients with chronic anal fissure: prospective, randomized, controlled trial of the extent of internal anal sphincter division during lateral sphincterotomy. World Journal of Surgery. Oct. 2007;31(10):2052-7. [pmid: 17665247].
2 Boccasanta P, Venturi M, Barbieri S, et al. Impact of new technologies on the clinical and functional outcome of Altemeier's procedure: a randomized, controlled trial. Diseases of the Colon & Rectum. May. 2006;49(5):652-60. [pmid: 16575620].
3 Zimmerman DD, Gosselink MP, Hop WC, et al. Impact of two different types of anal retractor on fecal continence after fistula repair: a prospective, randomized, clinical trial. Diseases of the Colon & Rectum. Dec. 2003;46(12):1674-9. [pmid: 14668594].
4 Ho YH, Seow-Choen F, Tan M. Colonic J-pouch function at six months versus straight coloanal anastomosis at two years: randomized controlled trial. World Journal of Surgery. Jul. 2001;25(7):876-81. [pmid: 11572027].
5 Ho YH, Yu S, Ang ES, et al. Small colonic J-pouch improves colonic retention of liquids--randomized, controlled trial with scintigraphy. Diseases of the Colon & Rectum. Jan. 2002;45(1):76-82. [pmid: 11786768].
6 Meyer S, Hohlfeld P, Achtari C, et al. Pelvic floor education after vaginal delivery. Obstetrics & Gynecology. May. 2001;97(5 Pt 1):673-7. [pmid: 11339914].
7 Chassagne P, Jego A, Gloc P, et al. Does treatment of constipation improve faecal incontinence in institutionalized elderly patients?. Age & Ageing. Mar. 2000;29(2):159-64. [pmid: 10791451].
8 Ouslander JG, Simmons S, Schnelle J, et al. Effects of prompted voiding on fecal continence among nursing home residents. Journal of the American Geriatrics Society. Apr. 1996;44(4):424-8. [pmid: 8636590].
9 Deen KI, Grant E, Billingham C, et al. Abdominal resection rectopexy with pelvic floor repair versus perineal rectosigmoidectomy and pelvic floor repair for full-thickness rectal prolapse. British Journal of Surgery. Feb. 1994;81(2):302-4. [pmid: 8156369].
10 Miner PB, Donnelly TC, Read NW. Investigation of mode of action of biofeedback in treatment of fecal incontinence. Digestive Diseases & Sciences. Oct. 1990;35(10):1291-8. [pmid: 2209296].
11 Markland AD, Richter HE, Burgio KL, et al. Weight loss improves fecal incontinence severity in overweight and obese women with urinary incontinence. International Urogynecology Journal. Sep. 2011;22(9):1151-7. [pmid: 21567259].
12 Glazener CM, Herbison GP, MacArthur C, et al. Randomised controlled trial of conservative management of postnatal urinary and faecal incontinence: six year follow up. BMJ. Feb. 12. 2005;330(7487):337. [pmid: 15615766].
13 Glazener CM, Herbison GP, Wilson PD, et al. Conservative management of persistent postnatal urinary and faecal incontinence: randomised controlled trial. BMJ. Sep. 15. 2001;323(7313):593-6. [pmid: 11557703].
14 Glazener CM, MacArthur C, Hagen S, et al. Twelve-year follow-up of conservative management of postnatal urinary and faecal incontinence and prolapse outcomes: randomised controlled trial. BJOG: An International Journal of Obstetrics & Gynaecology. Jan. 2014;121(1):112-20. [pmid: 24148807].
15 Scaglia M, Delaini G, Destefano I, et al. Fecal incontinence treated with acupuncture - a pilot study. Autonomic Neuroscience: Basic and Clinical. 28. Jan. 2009;145(1-2):89-92. [pmid: 19059009].
16 Melenhorst J, Koch SM, Uludag O, et al. Is a morphologically intact anal sphincter necessary for success with sacral nerve modulation in patients with faecal incontinence?. Colorectal Disease. Mar. 2008;10(3):257-62. [pmid: 17949447].
17 Chan MK, Tjandra JJ. Sacral nerve stimulation for fecal incontinence: external anal sphincter defect vs. intact anal sphincter. Diseases of the Colon & Rectum. Jul. 2008;51(7):1015-24. discussion 24-5. [pmid: 18484136].
18 Terra MP, Dobben AC, Berghmans B, et al. Electrical stimulation and pelvic floor muscle training with biofeedback in patients with fecal incontinence: a cohort study of 281 patients. Diseases of the Colon & Rectum. Aug. 2006;49(8):1149-59. [pmid: 16773492].
19 Allgayer H, Dietrich CF, Rohde W, et al. Prospective comparison of short- and long-term effects of pelvic floor exercise/biofeedback training in patients with fecal incontinence after surgery plus irradiation versus surgery alone for colorectal cancer: clinical, functional and endoscopic/endosonographic findings. Scandinavian Journal of Gastroenterology. Oct. 2005;40(10):1168-75. [pmid: 16165701].
20 Giordano P, Renzi A, Efron J, et al. Previous sphincter repair does not affect the outcome of repeat repair. Diseases of the Colon & Rectum. May. 2002;45(5):635-40. [pmid: 12004213].
21 Efron JE. The SECCA procedure: a new therapy for treatment of fecal incontinence. Surgical Technology International. 2004;13:107-10. [pmid: 15744681].
22 Jorge JM, Wexner SD, James K, et al. Recovery of anal sphincter function after the ileoanal reservoir procedure in patients over the age of fifty. Diseases of the Colon & Rectum. Oct. 1994;37(10):1002-5. [pmid: 7924704].

## Off Topic (n = 8)

1 Matzel KE, Stadelmaier U, Hohenfellner M, et al. Chronic sacral spinal nerve stimulation for fecal incontinence: long-term results with foramen and cuff electrodes. Diseases of the Colon & Rectum. Jan. 2001;44(1):59-66. [pmid: 11805564].
2 Santoro GA, Eitan BZ, Pryde A, et al. Open study of low-dose amitriptyline in the treatment of patients with idiopathic fecal incontinence. Diseases of the Colon & Rectum. Dec. 2000;43(12):1676-81. discussion 81-2. [pmid: 11156450].
3 Miller R, Bartolo DC, Locke-Edmunds JC, et al. Prospective study of conservative and operative treatment for faecal incontinence. British Journal of Surgery. Feb. 1988;75(2):101-5. [pmid: 3349291].
4 Wexner SD, Hull T, Edden Y, et al. Infection rates in a large investigational trial of sacral nerve stimulation for fecal incontinence. Journal of Gastrointestinal Surgery. Jul. 2010;14(7):1081-9. [pmid: 20354809].
5 Poirier M, Abcarian H, Nelson R. Malone antegrade continent enema: an alternative to resection in severe defecation disorders. Diseases of the Colon & Rectum. Jan. 2007;50(1):22-8. [pmid: 17115341].
6 Takahashi T, Garcia-Osogobio S, Valdovinos MA, et al. Extended two-year results of radio-frequency energy delivery for the treatment of fecal incontinence (the Secca procedure). Diseases of the Colon & Rectum. Jun. 2003;46(6):711-5. [pmid: 12794570].
7 Riss S, Stift A, Teleky B, et al. Long-term anorectal and sexual function after overlapping anterior anal sphincter repair: A case-match study. Diseases of the Colon and Rectum. June. 2009;52(6):1095-100. [pmid: 19581852].
8 Thomas GP, Norton C, Nicholls RJ, et al. A pilot study of transcutaneous sacral nerve stimulation for faecal incontinence. Colorectal Disease. November. 2013;15(11):1406-9. [pmid: 23910042].

## No Patient-Reported Outcomes/Data Not Usable (n = 20)

1 Bouguen G, Ropert A, Laine F, et al. Effects of transcutaneous tibial nerve stimulation on anorectal physiology in fecal incontinence: a double-blind placebo-controlled cross-over evaluation. Neurogastroenterology & Motility. Feb. 2014;26(2):247-54. [pmid: 24304363].
2 Bharucha AE, Edge J, Zinsmeister AR. Effect of nifedipine on anorectal sensorimotor functions in health and fecal incontinence. American Journal of Physiology - Gastrointestinal & Liver Physiology. Jul. 2011;301(1):G175-80. [pmid: 21493732].
3 Fox M, Stutz B, Menne D, et al. The effects of loperamide on continence problems and anorectal function in obese subjects taking orlistat. Digestive Diseases & Sciences. Sep. 2005;50(9):1576-83. [pmid: 16133954].
4 Cheetham MJ, Kamm MA, Phillips RK. Topical phenylephrine increases anal canal resting pressure in patients with faecal incontinence. Gut. Mar. 2001;48(3):356-9. [pmid: 11171825].
5 Vaizey CJ, Kamm MA, Roy AJ, et al. Double-blind crossover study of sacral nerve stimulation for fecal incontinence. Diseases of the Colon & Rectum. Mar. 2000;43(3):298-302. [pmid: 10733109].
6 Heymen S, Pikarsky AJ, Weiss EG, et al. A prospective randomized trial comparing four biofeedback techniques for patients with faecal incontinence. Colorectal Disease. 2000;2(2):88-92. [pmid: 23577991].
7 Deen KI, Kumar D, Williams JG, et al. Randomized trial of internal anal sphincter plication with pelvic floor repair for neuropathic fecal incontinence. Diseases of the Colon & Rectum. Jan. 1995;38(1):14-8. [pmid: 7813338].
8 Oya M, Ortiz J, Grant EA, et al. A video proctographic assessment of the changes in pelvic floor function following three forms of repair for post-obstetric neuropathic faecal incontinence. Digestive Surgery. 1994;11(1):20-4.
9 Tobin GW, Brocklehurst JC. Faecal incontinence in residential homes for the elderly: prevalence, aetiology and management. Age & Ageing. Jan. 1986;15(1):41-6. [pmid: 3953330].
10 Latimer PR, Campbell D, Kasperski J. A components analysis of biofeedback in the treatment of fecal incontinence. Biofeedback & Self Regulation. Sep. 1984;9(3):311-24. [pmid: 6525357].
11 Harford WV, Krejs GJ, Santa Ana CA, et al. Acute effect of diphenoxylate with atropine (Lomotil) in patients with chronic diarrhea and fecal incontinence. Gastroenterology. Mar. 1980;78(3):440-3. [pmid: 7351282].
12 Collins E, Hibberts F, Lyons M, et al. Outcomes in non-surgical management for bowel dysfunction. British Journal of Nursing. 2014 Jul 24-Aug 13. 23(14):776-80. [pmid: 25062312].
13 Oom DMJ, Steensma AB, Van Lanschot JJB, et al. Is sacral neuromodulation for fecal incontinence worthwhile in patients with associated pelvic floor injury?. Diseases of the Colon and Rectum. April. 2010;53(4):422-7. [pmid: 20305441].
14 Lacima G, Pera M, Amador A, et al. Long-term results of biofeedback treatment for faecal incontinence: a comparative study with untreated controls. Colorectal Disease. Aug. 2010;12(8):742-9. [pmid: 19486084].
15 Oberwalder M, Dinnewitzer A, Nogueras JJ, et al. Imbrication of the external anal sphincter may yield similar functional results as overlapping repair in selected patients. Colorectal Disease. Oct. 2008;10(8):800-4. [pmid: 18384424].
16 Rasmussen OO, Puggaard L, Christiansen J. Anal sphincter repair in patients with obstetric trauma: Age affects outcome. Diseases of the Colon and Rectum. February. 1999;42(2):193-5. [pmid: 10211495].
17 Orrom WJ, Miller R, Cornes H, et al. Comparison of anterior sphincteroplasty and postanal repair in the treatment of idiopathic fecal incontinence. Diseases of the Colon & Rectum. Apr. 1991;34(4):305-10. [pmid: 2007347].
18 Ctercteko GC, Fazio VW, Jagelman DG, et al. Anal sphincter repair: a report of 60 cases and review of the literature. Australian & New Zealand Journal of Surgery. Sep. 1988;58(9):703-10. [pmid: 3074772].
19 Myers JB, Hu EM, Elliott SP, et al. Short-term outcomes of Chait Trapdoor for antegrade continence enema in adults. Urology. Jun. 2014;83(6):1423-6. [pmid: 24703460].
20 Fleshman JW, Peters WR, Shemesh EI, et al. Anal sphincter reconstruction: anterior overlapping muscle repair. Diseases of the Colon & Rectum. Sep. 1991;34(9):739-43. [pmid: 1914735].

## No Comparator or Inappropriate Comparator (n = 6)

1 Leroi AM, Siproudhis L, Etienney I, et al. Transcutaneous electrical tibial nerve stimulation in the treatment of fecal incontinence: a randomized trial (CONSORT 1a). American Journal of Gastroenterology. Dec. 2012;107(12):1888-96. [pmid: 23032981].
2 George AT, Kalmar K, Sala S, et al. Randomized controlled trial of percutaneous versus transcutaneous posterior tibial nerve stimulation in faecal incontinence. British Journal of Surgery. Feb. 2013;100(3):330-8. [pmid: 23300071].
3 Lombardi G, Del Popolo G, Cecconi F, et al. Clinical outcome of sacral neuromodulation in incomplete spinal cord-injured patients suffering from neurogenic bowel dysfunctions. Spinal Cord. February. 2010;48(2):154-9. [pmid: 19668257].
4 MacLeod JH. Management of anal incontinence by biofeedback. Gastroenterology. Aug. 1987;93(2):291-4. [pmid: 3596165].
5 MacLeod JH. Biofeedback in the management of partial anal incontinence. Diseases of the Colon & Rectum. Apr. 1983;26(4):244-6. [pmid: 6839894].
6 Norton C, Kamm MA. Outcome of biofeedback for faecal incontinence. [Erratum appears in Br J Surg 2000 Feb;87(2):249]. British Journal of Surgery. Sep. 1999;86(9):1159-63. [pmid: 10504370].

## Treatment Not FDA Approved (n = 10)

1 Maeda Y, Vaizey CJ, Kamm MA. Pilot study of two new injectable bulking agents for the treatment of faecal incontinence. Colorectal Disease. Mar. 2008;10(3):268-72. [pmid: 17655723].
2 Siproudhis L, Morcet J, Laine F. Elastomer implants in faecal incontinence: a blind, randomized placebo-controlled study. Alimentary Pharmacology & Therapeutics. May. 1. 2007;25(9):1125-32. [pmid: 17439514].
3 Bond C, Youngson G, MacPherson I, et al. Anal plugs for the management of fecal incontinence in children and adults: a randomized control trial. Journal of Clinical Gastroenterology. Jan. 2007;41(1):45-53. [pmid: 17198065].
4 Tjandra JJ, Lim JF, Hiscock R, et al. Injectable silicone biomaterial for fecal incontinence caused by internal anal sphincter dysfunction is effective. Diseases of the Colon & Rectum. Dec. 2004;47(12):2138-46. [pmid: 15657666].
5 Norton C, Kamm MA. Anal plug for faecal incontinence. Colorectal Dis. Sep. 2001;3(5):323-7. [pmid: 12790954].
6 Koch SM, Melenhorst J, van Gemert WG, et al. Prospective study of colonic irrigation for the treatment of defaecation disorders. British Journal of Surgery. Oct. 2008;95(10):1273-9. [pmid: 18720454].
7 Cazemier M, Felt-Bersma RJ, Mulder CJ. Anal plugs and retrograde colonic irrigation are helpful in fecal incontinence or constipation. World Journal of Gastroenterology. Jun. 14. 2007;13(22):3101-5. [pmid: 17589927].
8 Rongen MJGM, Adang EMM, Gerritsen van der Hoop A, et al. One step vs two-step procedure in dynamic graciloplasty. Colorectal Disease. 2001;3(1):51-7. [pmid: 12791022].
9 Michot F, Lefebure B, Bridoux V, et al. Artificial anal sphincter for severe fecal incontinence implanted by a transvaginal approach: experience with 32 patients treated at one institution. Diseases of the Colon & Rectum. Aug. 2010;53(8):1155-60. [pmid: 20628279].
10 Lehur PA, Glemain P, Bruley des Varannes S, et al. Outcome of patients with an implanted artificial anal sphincter for severe faecal incontinence. A single institution report. International Journal of Colorectal Disease. 1998;13(2):88-92. [pmid: 9638494].

## Other (n = 9)

1 Matzel KE, Stadelmaier U, Hohenfellner M, et al. Chronic sacral spinal nerve stimulation for fecal incontinence: long-term results with foramen and cuff electrodes. Diseases of the Colon & Rectum. Jan. 2001;44(1):59-66. [pmid: 11805564].
2 Santoro GA, Eitan BZ, Pryde A, et al. Open study of low-dose amitriptyline in the treatment of patients with idiopathic fecal incontinence. Diseases of the Colon & Rectum. Dec. 2000;43(12):1676-81. discussion 81-2. [pmid: 11156450].
3 Miller R, Bartolo DC, Locke-Edmunds JC, et al. Prospective study of conservative and operative treatment for faecal incontinence. British Journal of Surgery. Feb. 1988;75(2):101-5. [pmid: 3349291].
4 Wexner SD, Hull T, Edden Y, et al. Infection rates in a large investigational trial of sacral nerve stimulation for fecal incontinence. Journal of Gastrointestinal Surgery. Jul. 2010;14(7):1081-9. [pmid: 20354809].
5 Poirier M, Abcarian H, Nelson R. Malone antegrade continent enema: an alternative to resection in severe defecation disorders. Diseases of the Colon & Rectum. Jan. 2007;50(1):22-8. [pmid: 17115341].
6 Takahashi T, Garcia-Osogobio S, Valdovinos MA, et al. Extended two-year results of radio-frequency energy delivery for the treatment of fecal incontinence (the Secca procedure). Diseases of the Colon & Rectum. Jun. 2003;46(6):711-5. [pmid: 12794570].
7 Riss S, Stift A, Teleky B, et al. Long-term anorectal and sexual function after overlapping anterior anal sphincter repair: A case-match study. Diseases of the Colon and Rectum. June. 2009;52(6):1095-100. [pmid: 19581852].
8 Ortiz H, Armendariz P, DeMiguel M, et al. Prospective study of artificial anal sphincter and dynamic graciloplasty for severe anal incontinence. International Journal of Colorectal Disease. Jul. 2003;18(4):349-54. [pmid: 12774251].
9 Thomas GP, Norton C, Nicholls RJ, et al. A pilot study of transcutaneous sacral nerve stimulation for faecal incontinence. Colorectal Disease. November. 2013;15(11):1406-9. [pmid: 23910042].