# Search Strings

## Database: Ovid MEDLINE(R)

### Search Strategy: RCTs

1. meta analysis as topic/
2. meta-analy$.tw.
3. metaanaly$.tw.
4. meta-analysis/
5. (systematic adj (review$1 or overview$1)).tw.
6. exp Review Literature as Topic/
7. or/1-6
8. cochrane.ab.
9. embase.ab.
10. (psychlit or psyclit).ab.
11. (psychinfor or psycinfo).ab.
12. or/8-11
13. reference list$.ab.
14. bibliograph$.ab.
15. hand search.ab.
16. relevant journals.ab.
17. manual search$.ab.
18. or/13-17
19. selection criteria.ab.
20. data extraction.ab.
21. 19 or 20
22. review/
23. 21 and 22
24. comment/
25. letter/
26. editorial/
27. animal/
28. human/
29. 27 not (28 and 27)
30. or/24-26,29
31. 7 or 12 or 18 or 23
32. 31 not 30
33. randomized controlled trials as topic/
34. randomized controlled trial/
35. random allocation/
36. double blind method/
37. single blind method/
38. clinical trial/
39. clinical trial, phase i.pt.
40. clinical trial, phase ii.pt.
41. clinical trial, phase iii.pt.
42. clinical trial, phase iv.pt.
43. controlled clinical trial.pt.
44. randomized controlled trial.pt.
45. multicenter study.pt.
46. clinical trial.pt.
47. exp Clinical trials as topic/
48. or/33-47
49. (clinical adj trial$).tw.
50. ((singl$ or doubl$ or treb$ or tripl$) adj (blind$3 or mask$3)).tw.
51. placebos/
52. placebo$.tw.
53. randomly allocated.tw.
54. (allocated adj2 random$).tw.
55. 49 or 50 or 51 or 52 or 53 or 54
56. 48 or 55
57. case report.tw.
58. case report.tw.
59. letter/
60. historical article/
61. 57 or 58 or 59 or 60
62. 56 not 61
63. exp cohort studies/
64. cohort$.tw.
65. controlled clinical trial.pt.
66. epidemiologic methods/
67. limit 66 to yr=1971-1983
68. 63 or 64 or 65 or 67
69. exp Fecal Incontinence/
70. f?ecal incontin*.ti,ab.
71. 69 or 70
72. 62 and 71
73. limit 72 to “all child (0 to 18 years)”
74. limit 73 to “all adult (19 plus years)”
75. 72 not 73
76. 75 or 74

## Database: Ovid MEDLINE(R)

### Search Strategy: Observational & Systematic Reviews

1. meta analysis as topic/
2. meta-analy$.tw.
3. metaanaly$.tw.
4. meta-analysis/
5. (systematic adj (review$1 or overview$1)).tw.
6. exp Review Literature as Topic/
7. or/1-6
8. cochrane.ab.
9. embase.ab.
10. (psychlit or psyclit).ab.
11. (psychinfor or psycinfo).ab.
12. or/8-11
13. reference list$.ab.
14. bibliograph$.ab.
15. hand search.ab.
16. relevant journals.ab.
17. manual search$.ab.
18. or/13-17
19. selection criteria.ab.
20. data extraction.ab.
21. 19 or 20
22. review/
23. 21 and 22
24. comment/
25. letter/
26. editorial/
27. animal/
28. human/
29. 27 not (28 and 27)
30. or/24-26,29
31. 7 or 12 or 18 or 23
32. 31 not 30
33. Epidemiologic studies/
34. exp cohort studies/
35. exp case control studies/
36. Case control.tw.
37. (cohort adj (study or studies)).tw.
38. contro*.tw.
39. Cohort analy$.tw.
40. (Follow up adj (study or studies)).tw.
41. (observational adj (study or studies)).tw.
42. Longitudinal.tw.
43. or/33-42
44. exp *Fecal Incontinence/
45. f?ecal incontin*.ti.
46. 44 or 45
47. 32 or 43
48. 46 and 47
49. limit 48 to (“all infant (birth to 23 months)” or “all child (0 to 18 years)”)
50. limit 49 to (“all adult (19 plus years)” or “young adult (19 to 24 years)” or “adult (19 to 44 years)” or “young adult and adult (19-24 and 19-44)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)”)
51. 48 not 49
52. 50 or 51
53. limit 52 to (autobiography or bibliography or biography or clinical conference or comment or congresses or consensus development conference or dataset or dictionary or directory or editorial or in vitro or interactive tutorial or interview or lectures or legal cases or letter or news or newspaper article or patient education handout or periodical index or portraits or validation studies or video-audio media or webcasts)
54. 52 not 53
55. 32 and 54
56. limit 55 to yr=“2007 -Current”
57. 43 and 54
58. limit 57 to yr=“2014 -Current”
59. (anal and incontin*).ti.
60. 43 and 59
61. 43 and 46 and 60
62. 61 not 60
63. 58
64. from 63 keep 1-33

## Database: Embase

### Search Strategy: RCTs

1. Clinical trial/
2. Randomized controlled trial/
3. Randomization/
4. Single blind procedure/
5. Double blind procedure/
6. Crossover procedure/
7. Placebo/
8. Randomi?ed controlled trial$.tw.
9. Rct.tw.
10. Random allocation.tw.
11. Randomly allocated.tw.
12. Allocated randomly.tw.
13. (allocated adj2 random).tw.
14. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13
15. Case study/
16. Case report.tw.
17. Abstract report/ or letter/
18. 15 or 16 or 17
19. 14 not 18
20. exp feces incontinence/
21. f?ec* incontinence.ti,ab.
22. 20 or 21
23. limit 22 to “therapy (maximizes specificity)”
24. 19 and 22
25. 23 or 24
26. limit 25 to (embryo <first trimester> or infant <to one year> or child <unspecified age> or preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years>)
27. limit 26 to (adult <18 to 64 years> or aged <65+ years>)
28. 25 not 26
29. 27 or 28
30. limit 29 to (book or book series or conference abstract or conference paper or conference proceeding or “conference review” or editorial or letter or note or report or “review” or short survey or trade journal) (747)
31. 29 not 30 (893)

## Database: Embase

### Search Strategy: Observational & Systematic Reviews

1. exp cohort analysis/ (174551)
2. exp longitudinal study/ (63150)
3. exp prospective study/ (242937)
4. exp follow up/ (756554)
5. cohort$.tw. (402905)
6. 1 or 2 or 3 or 4 or 5 (1292797)
7. exp case-control study/ (84810)
8. (case$ and control$).tw. (358942)
9. 7 or 8 (386956)
10. (case$ and series).tw. (126465)
11. exp review/ (1524716)
12. (literature adj3 review$).ti,ab. (165004)
13. exp meta analysis/ (79651)
14. exp “Systematic Review”/ (80673)
15. 11 or 12 or 13 or 14 (1686250)
16. (medline or embase or pubmed or cinahl or amed or psychlit or psychinfo or scisearch or cochrane).ti,ab. (110973)
17. retracted article/ (6623)
18. 16 or 17 (117548)
19. 15 and 18 (87911)
20. (systematic$ adj2 (review$ or overview)).ti,ab. (77973)
21. (meta?anal$ or meta anal$ or metaanal$ or metanal$).ti,ab. (84784)
22. 19 or 20 or 21 (176214)
23. exp *feces incontinence/ (4452)
24. f?ecal incontin*.ti. (2291)
25. 23 or 24 (4492)
26. limit 25 to (meta analysis or “systematic review”) (67)
27. 22 and 25 (129)
28. 26 or 27 (143)
29. 6 or 9 or 10 or 28 (1684571)
30. 25 and 29 (1257)
31. limit 30 to yr=“1980 -Current” (1257)
32. limit 31 to (embryo <first trimester> or infant <to one year> or child <unspecified age> or preschool child <1 to 6 years> or school child <7 to 12 years>) (153)
33. limit 32 to (adult <18 to 64 years> or aged <65+ years>) (47)
34. 31 not 32 (1104)
35. 33 or 34 (1151)
36. limit 35 to (book or book series or conference abstract or conference paper or conference proceeding or “conference review” or editorial or erratum or letter or note or report or “review” or short survey or trade journal) (522)
37. 35 not 36 (629)
38. 15 and 25 (718)
39. 28 (143)
40. limit 39 to yr=“2007 -Current” (97)
41. limit 40 to (book or book series or conference abstract or conference paper or conference proceeding or “conference review” or editorial or erratum or letter or note or short survey or trade journal) (18)
42. from 37 keep 1-629 (629)
43. 40 not 41 (79)
44. 37 (629)
45. from 44 keep 1-629 (629)

## Database: Cochrane Library

Search Strategy:

‘Fecal Incontinence’* in title, abstract, keyword

*automatically also searches for ‘faecal incontinence’

### AMED: Allied and Complementary Medicine

AMED-RCTs
1. meta analysis
2. meta-analysis
3. meta analys$.tw
4. meta-analys$.tw
5. (systematic adj (review$1 or overview$1).tw
6. Or/1-5
7. Cochrane.ab
8. Embase.ab
9. (psychlit or psyclit).ab
10. (psychinfor or psycinfo).ab
11. Or/7-10
12. Reference list$.ab
13. Bibliograph$.ab
14. Hand search.ab
15. Relevant journals.ab
16. Manual search$.ab
17. Or/12-16
18. Selection criteria.ab
19. Data extraction.ab
20. 18 or 19
21. Comment.tw
22. Letter.tw
23. Editorial.tw
24. Animal/
25. Humans/
26. 25 not (24 and 25)
27. 21-23,26
28. 6 or 11 or 17 or 20
29. 28 not 27
30. Randomized controlled trial/
31. Randomized controlled trial.tw
32. Random allocation/
33. Double blind method/
34. Single blind method/
35. Controlled clinical trial.pt
36. Randomized controlled trial.pt
37. Multicenter study.pt
38. Clinical trial.pt
39. Exp clinical trials
40. Or 30-39
41. (clinical adj trial$).tw
42. (singl$ or doubl$ or treb$ or tripl$).tw
43. 42 adj (blind$3 or mask$3).tw
44. Placebos/
45. Placebo$.tw
46. Randomly allocated.tw
47. (allocated adj2 random$).tw
48. Or/41-47
49. 40 or 48
50. Case report.tw
51. Letter.tw
52. Letter.pt
53. 50 or 51 or 52
54. 49 not 53
55. Exp cohort studies/
56. Cohort$.tw
57. Controlled clinical trial.pt
58. Epidemiologic methods/
59. 55 or 56 or 57 or 58
60. Exp Fecal Incontinence/
61. F?ecal incontin*.ti,ab
62. 60 or 61
63. 54 and 62

AMED Observational
1. meta analysis
2. meta-analysis
3. meta analys$.tw
4. meta-analys$.tw
5. (systematic adj (review$1 or overview$1).tw
6. Or/1-5
7. Cochrane.ab
8. Embase.ab
9. (psychlit or psyclit).ab
10. (psychinfor or psycinfo).ab
11. Or/7-10
12. Reference list$.ab
13. Bibliograph$.ab
14. Hand search.ab
15. Relevant journals.ab
16. Manual search$.ab
17. Or/12-16
18. Selection criteria.ab
19. Data extraction.ab
20. 18 or 19
21. Comment.tw
22. Letter.tw
23. Editorial.tw
24. Animal/
25. Humans/
26. 25 not (24 and 25)
27. 21-23,26
28. 6 or 11 or 17 or 20
29. 28 not 27
30. epidemiologic studies.tw
31. exp cohort studies/
32. exp case control studies/
33. case control studies/
34. retrospective studies or prospective studies or follow up studies
35. longitudinal studies/
36. case control.tw
37. (cohort adj (study or studies)).tw
38. Contro*.tw
39. Cohort analy$.tw
40. (follow up adj (study or studies)).tw
41. (observational adj (study or studies)).tw
42. Longitudinal.tw
43. Or/30-42
44. Exp fecal incontinence
45. F?ecal incontin*.ti
46. 44 or 45
47. 29 or 43
48. 46 and 47

## PedRO

Search strategy: fecal incontinence or faecal incontinence

## CINAHL: Cumulative Index to Nursing and Allied Health

Table B1 Search strings used in Cumulative Index to Nursing and Allied Health

# | Query | Limiters/Expanders | Last Run Via
S11 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 | Limiters - Clinical Queries: Therapy - High Sensitivity Narrow by SubjectAge: - all adult Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text
S10 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 | Limiters - Clinical Queries: Therapy - High Sensitivity Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text
S9 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 | Limiters - Published Date: 19800101-20141231 Narrow by SubjectAge: - all adult Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text
S8 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 | Limiters - Published Date: 19800101-20141231 Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text
S7 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text
S6 | TI anal and incontinence | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text
S5 | TI faecal and incontinence | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text
S4 | TI fecal and incontinence | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text
S3 | Anal incontinence | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text
S2 | (MH “Fecal Incontinence”) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text
S1 | fecal incontinence OR faecal incontinence | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text