# Analytic Framework for Treatments for Fecal Incontinence

Figure A1 depicts the two key questions within the context of the PICOTS described in Table 1 of the report. The figure above illustrates how the use of single or multimodal treatments for fecal incontinence may improve outcomes for adults with fecal incontinence. This systematic literature review included adults who underwent treatment for fecal incontinence. The Key Question 1 final health outcome categories include quality of life (health-related or specific to fecal incontinence), FI severity and impact (continence measures), urgency, pain, social activity, sexual function, the use of coping behaviors to manage fecal incontinence, and emotional or psychological measures. Adverse effects of drugs or interventions may also occur at any point after the treatment is initiated; these were examined in Key Question 2.

Figure A1 Analytic framework for treatments for fecal incontinence

HRQoL: Health-realated Quality of Life

FIQoL: Fecal Incontinence Quality of Life

Figure A1 depicts the two key questions within the context of the PICOTS described in Table 1 of the report. The figure above illustrates how the use of single or multimodal treatments for fecal incontinence may improve outcomes for adults with fecal incontinence. This systematic literature review included adults who underwent treatment for fecal incontinence. The Key Question 1 final health outcome categories include quality of life (health-related or specific to fecal incontinence), FI severity and impact (continence measures), urgency, pain, social activity, sexual function, the use of coping behaviors to manage fecal incontinence, and emotional or psychological measures. Adverse effects of drugs or interventions may also occur at any point after the treatment is initiated; these were examined in Key Question 2.