# Abbreviations

ABL: Accidental bowel leakage
ABS: Artificial bowel sphincter
ACE: Antegrade colonic irrigation
AE: Adverse effect
AHRQ: Agency for Healthcare Research and Quality
AMED: Allied and Complementary Medicine
CENTRAL: Cochrane Central Register of Controlled Trials
CER: Comparative effectiveness review
CCFIS: Cleveland Clinic Fecal Incontinence Score
FDA: Food and Drug Administration
FI: Fecal incontinence
FICA: Fecal Incontinence and Continence Assessment
FIQL: Fecal Incontinence Quality of Life Instrument
FISI: Fecal Incontinence Severity Index
GI: Gastrointestinal
KQ: Key Question
MID: Minimum important difference
OBS: Observational Studies
PEDro: Physiotherapy Evidence Database
PFMT: Pelvic floor muscle training
PFMT-BF: Pelvic floor muscle training with biofeedback
PICOTS: Population, Intervention, Comparator, Outcomes, Timing, Setting
PTNS: Posterior tibial nerve stimulation
RCT: Randomized controlled trial
SCI: Spinal cord injuries
SECCA: Radiofrequency anal sphincter remodeling
SIP: Scientific Information Packet
SNS: Sacral nerve stimulation
SOE: Strength of evidence
TEP: Technical expert panel