# Results

## Literature Searches

The search and selection of articles are summarized in the study flow diagram (Figure 2). There were 4,406 citations identified at the title and abstract level. Of these, 221 articles appeared to meet inclusion criteria and were selected for full-text review. Following review at the full-text level, a total of 19 studies met the inclusion criteria (Appendix B). Primary reasons for exclusion of the articles reviewed at the full-text level were wrong intervention types, such as telephone care only, temporary postsurgery care, or visits by a social worker or home care nurse only (Appendix C).

Figure 2 Study flow diagram

This figure is a literature flow diagram depicting the search and selection of articles for the present review. The diagram shows that 4,833 abstracts of potentially relevant articles were identified using Ovid MEDLINE, CINAHL, Clinical Trials.gov, and Cochrane Database of Systematic Reviews. There were 4,833 articles identified in the search. After duplicates were removed, 4,406 articles were reviewed at the abstract level and 4,185 abstracts were excluded. The remaing 221 articles were reviewed at the full-text level after excluding 201 non-relevant full text and background articles. The following number of studies were included: 19 studies (in 20 publications).

## Included Studies

The study flow diagram represented in Figure 2 documents how many studies were identified in the search and how many were reviewed at each stage. The triage and review process resulted in the inclusion of 19 studies reported in 20 articles.29-48

As many of the most applicable search terms were broad, at the triage stage most of the abstracts excluded were of studies that were clearly not about home-based primary care (HBPC). These included studies about other models of care, such as medical homes, as the indexing in literature databases for these studies includes similar terms. At the full-text review level, most of the excluded studies were about interventions that did not meet our inclusion criteria. Another group of excluded publications were articles that contained descriptions of programs but did not include an evaluation component with any data on outcomes.

Table 3, the text below, and the Evidence Table in Appendix E contain information about the 19 included studies. Table 3 shows that the most common study design is retrospective pre-post studies with no comparison group. Two of the 19 studies were randomized controlled trials (RCTs). Most of the studies were conducted in the United States (16 studies) with eight of these conducted by the U.S. Department of Veterans Affairs (VA). In addition, most studies were conducted in a single medical center or care delivery organization (e.g., one VA medical center or one health plan, not several or nationwide). All studies reported multiple outcomes; however, the most commonly studied outcome was the impact of HBPC on hospitalizations.

Table 3 Key characteristics of included studies

Key Characteristics | Study Information | Number of Studies (Total N=19) | References^a^
Study Designs | RCTs | 2 | 35,39
Study Designs | Retrospective cohort | 5 | 29,36-38,40,41
Study Designs | Prospective pre/post | 5 | 42-46
Study Designs | Retrospective pre/post | 7 | 30-34,47,48
Length of Followup | 1 week up to 3 months | 2 | 29,48
Length of Followup | 3 months to up to 6 months | 2 | 34,42
Length of Followup | 6 months to up to 1 year | 5 | 30,31,33,39-41
Length of Followup | 1 year or more | 10 | 32,35-38,43-47
Setting/Location | VA/United States | 8 | 31,33,34,37-39,42,43
Setting/Location | Non-VA/United States | 8 | 30,32,35,36,44-46,48
Setting/Location | Denmark | 2 | 29,40,41
Setting/Location | Canada | 1 | 47
Sites | Multiple sites | 7 | 29,31,34,37-39,42
Sites | Single site | 12 | 30,32,33,35,36,40,41,43-48
Outcomes (studies can have multiple outcomes) | Hospitalizations | 11 | 32-39,43,47,48
Outcomes (studies can have multiple outcomes) | Hospital bed days | 6 | 31,33,34,37,45,47
Outcomes (studies can have multiple outcomes) | Hospital readmission | 3 | 31,39,45
Outcomes (studies can have multiple outcomes) | Emergency visits | 6 | 32,33,35,36,43,47
Outcomes (studies can have multiple outcomes) | Nursing home admissions | 1 | 48
Outcomes (studies can have multiple outcomes) | Nursing home days | 2 | 31,36
Outcomes (studies can have multiple outcomes) | Specialty visits | 2 | 32,36
Outcomes (studies can have multiple outcomes) | Number of home visits | 3 | 31,32,40,41
Outcomes (studies can have multiple outcomes) | Cost of care | 6 | 31,32,36,37,39,45
Outcomes (studies can have multiple outcomes) | Mortality | 2 | 35,36
Outcomes (studies can have multiple outcomes) | Function | 3 | 30,35,39
Outcomes (studies can have multiple outcomes) | Disease management quality Indicators | 1 | 34
Outcomes (studies can have multiple outcomes) | Caregiver outcomes | 4 | 39,42-44
Outcomes (studies can have multiple outcomes) | Satisfaction | 4 | 30,34,37,39
Outcomes (studies can have multiple outcomes) | Symptoms | 3 | 35,45,46
Outcomes (studies can have multiple outcomes) | SF-36 | 2 | 35,39
Outcomes (studies can have multiple outcomes) | Place of death | 3 | 29,40,41,47
Outcomes (studies can have multiple outcomes) | Terminal declaration (certification of terminal status) | 1 | 29

RCT = randomized controlled trial, VA = U.S. Department of Veterans Affairs

a One study was the subject of two publications.

Some other characteristics were not reported in detail in the article, but do not appear to vary across the studies so they are not included in Table 3. Examples are specifics about the patient's home and the age of eligible patients. All the HBPC interventions by definition had to include care provided in the patients' homes. We allowed “home” to be defined broadly to include settings such as assisted living or adult foster homes. None of the included studies provided detailed information about the homes of their patients. So while it seems that homes other than private houses and apartments were not excluded, it is not clear how many if any of the patients were residing in settings other than traditional housing.

Similarly, while we restricted our review to HBPC for adults (18 years old or older), most of the studies reported on elderly patients and included no or very few younger adults. The reasons for this varied. In some cases either the program or the study set an age for inclusion (e.g., 65 or older,35 67 or older,38 75 or older 47). In other cases because Medicare data were used and most people eligible for Medicare are over 65, the studies included only small numbers of younger adults (e.g., in the study by de Jonge 2.4% of the included patients were under 65^36^). Even when the program and the study were available to adults of all ages, the majority were older (e.g., the study with the most adult but not elderly patients was about cancer patients and 75% of patients were over 60 while 25% were 18 to 59^29^).

Additional information such as the inclusions and exclusion criteria for each study and the number of patients screened, recruited, followed, and included in the analyses are presented in Appendix E.

## Effects of HBPC Interventions

### Key Question 1 Among adults with chronic conditions that are serious or disabling, what are the effects (positive and negative) of home-based primary care interventions on (a) health outcomes, (b) patient and caregiver experience, and (c) utilization of services and costs?

#### Overview of Findings

- Health Outcomes: No significant differences in function or mortality (strength of evidence: low) and insufficient evidence about HBPC impact on symptoms.
- Patient and Caregiver Experience: Satisfaction with care, quality of life, and caregiver outcomes were better with HBPC (strength of evidence: low).
- Utilization of Services:
  ○ HBPC reduced hospitalization and hospital days (strength of evidence: moderate).
  ○ Some evidence suggested that numbers of emergency visits and specialty visits are lower with HBPC (strength of evidence: low).
  ○ Evidence did not indicate HBPC reduces hospital readmissions, and the impact on costs were mixed, with higher quality studies reporting cost savings (strength of evidence: low).
  ○ There was insufficient evidence on which to base a conclusion about the impact of HBPC on nursing home admissions and nursing home days (insufficient evidence).
  ○ HBPC results in cost saving for highest risk, most frail patients. (strength of evidence: low).
- The only identified study to directly examine negative unintended consequences reported that none of the patients and caregivers interviewed (n=31) stated they experienced restriction of services (insufficient evidence).

Key results from the included studies that addressed Key Question 1 are presented in Table 4. This table organizes the study results by outcome (rows) and by the quality (columns) based on an assessment of risk of bias or quality of the study. We used this format so that it would be easier to identify if trends in the results vary by the quality of the studies. This is important because syntheses can be potentially flawed when studies of different quality are given equal weight. Specifically, it is possible to conclude that the results are inconsistent or conflicting when looking across all studies, whereas the high quality studies may support a stronger conclusion. Additional information on the results is included in the evidence table in Appendix E. We present all results, including those from studies we rated as poor quality, in order to comprehensively represent the state of the literature. However, we focus on the high- and moderate-quality studies in our summary and conclusions, and we describe differences across studies and the potential implications of these differences in the Discussion. The strength of evidence assessment cited in the overview above is an assessment of the body of evidence, which considers individual study quality as well as other factors, such as the consistency and precision of the findings. (See Appendix A for more detail on the methods and Appendix G for the strength of evidence rating for each Key Question and outcome.)

Table 4 Effectiveness of home-based primary care interventions (Key Question 1): primary results by outcome and level of study quality (assessment of risk of bias) for individual studies^a^

Key Question | Outcome | Study Quality: Good | Study Quality: Fair | Study Quality: Poor
Key Question 1a : Health Outcomes | Function | ADLs: No significant difference (Counsell, 2007)35 | No significant difference (Hughes, 2000)39 | 21% improvement in ADLs No statistical test reported (Anetzberger, 2006)30
Key Question 1a : Health Outcomes | Symptoms | —— | Reduction in moderate to severe symptom burden % symptom free Pain 3 weeks: 25%, 12 weeks: 27.08% Depression 3: weeks 57.8%, 12 weeks: 50% Loss of Appetite: 3 weeks 20.69%, 12 weeks: 24.49% Anxiety 3 weeks: 58.62%, 12 weeks: 59.26% Tiredness 3 weeks: 45.10%, 12 weeks: 47.5% All p-values: p<0.01 (Ornstein, 2013)46 | ——
Key Question 1a : Health Outcomes | Mortality | 7% 24 months HBPC vs. 7.8% controls p=0.64 No significant difference (Counsell, 2007)35 Mortality during followup period HBPC (40%) Controls (36%) HR 1.06, p=0.44 (De Jonge, 2014)36 | —— | ——
Key Question 1b : Patient and Caregiver Experience | Satisfaction | No patient or caregiver reports of restrictions on services (Edes, 2014)37 | [underlined: Patient satisfaction] Terminally ill patients: no significant difference Nonterminally ill patients: HBPC group significantly better with 5 to 10 point increases in 5 of 6 dimensions (Hughes, 2000)39 | 94% would recommend program to others No statistical test reported (Anetzberger, 2006)30 98% rate care as “excellent” or “good” No statistical test reported (Cooper, 2007)34
Key Question 1b : Patient and Caregiver Experience | SF-36 Quality of Life | SF-36 scores at 24 months Improvements for intervention patients compared with usual care in 4 of 8 scale General health (0.2 vs. −2.3), p=0.045 Vitality (2.6 vs. −2.6), p=0 .001 Social functioning (3.0 vs. −2.3), p=0.008 Mental health (3.6 vs. −0.3), p=0.001 Also in the Mental Component Summary (2.1 vs. −0.3), p=0.001 (Counsell, 2007)35 | [underlined: Quality of Life] Terminally ill patients in HBPC group had significantly better scores in 6 of 8 SF-36 subscales Nonterminal: no significant difference (Hughes, 2000)39 | ——
Key Question 1b : Patient and Caregiver Experience | Caregiver Outcomes | —— | [underlined: Caregiver] Most caregiver outcomes favor the treatment group HBPC group improved in HR-QOL p<0.05 (Hughes, 2000)39 | Change in % needing assistance baseline to 9 months, p-value Transportation: 19.7, p=0.001 Daily chores: 26.8, p <0.001 Change in Caregiver Burden baseline to 9 months Physical burden: 1.90, p=0.006 Total burden: 3.84, p=0.017 (Ornstein, 2009)44
Key Question 1c : Utilization of Services | Hospitalizations | 43.7% decrease in hospitalizations (Chang, 2009)33 Hospital admission rates per 1000 patients (700 [n=474] vs. 740 [n=477]), p=0.66 (Counsell, 2007)35 HBPC 9% fewer hospitalizations, p=0.001 Hospitalization cost $17,805 vs. $22,096 p=0.001 (De Jonge, 2014)36 VA+Medicare hospital admissions per 100 patient-months 25.5% decrease (95% CI, -26.5 to -24.5) p<0.001 (Edes, 2014)37 5.8% absolute reduction in hospitalizations in year (95% CI, -9.3 to -2.3), decrease from 28.2% to 22.4%. Hazard ratio: 0.71 (0.57 to 0.89) (Edwards, 2014)38 | 7.8% increase in hospitalizations No statistical test reported (Beck 2009) 32 Change pre to post HBPC 59.5% reduction in Hospital admissions, p<0.001 (Rosenberg, 2012)47 Patients with ≥1 hospitalization Before enrollment 110 (61%) After enrollment 178 (38%), p<0.001 (Wajnberg, 2010)48 7.9%, p=0.07 (relative reduction in the proportion of HBPC patients admitted in the first 6 months, not sustained at 12 months) (Hughes, 2000)39 | 27% reduction in hospital admissions No p-values reported for any of the above results (Cooper, 2007)34 84% decrease in hospitalizations Pre: 822; post: 135 No statistical test reported (North, 2008)43
Key Question 1c : Utilization of Services | Hospital Bed Days/Length of Stay | 49.9% decrease in total number of days in hospital, p=0.001 (Chang, 2009)33 VA Medicare hospital days 36.5% decreased In a high risk for hospitalization group, (95% CI, -37.6 to -35.4) p<0.001 (Edes, 2014)37 | [underlined: Length of stay] 6.5 days pre; 6.45 days during intervention p=0.09 (Ornstein, 2011)45 61.7% reduction in hospital days p=0.004 (Rosenberg, 2012)47 | 59% reduction in hospital bed days no statistical test reported (Beales, 2009)31 69% reduction in hospital days No p-values reported for any of the above results (Cooper, 2007)34
Key Question 1c : Utilization of Services | Hospital Readmissions | —— | 11%, p=0.06 (relative reduction in mean number of readmissions at 6 months not sustained at 12 months) 22%, p=0.03 (relative reduction in mean number of readmissions at 6 months in the subgroup with severe disability) 22% relative decrease in readmissions per patient for HBPC at 6 months, p=0.03, not significant at 12 months (Hughes, 2000)39 Admissions that generated at least one 30-day readmissions 16.6% pre; 15.7% during intervention p=0.71 (Ornstein, 2011)45 | 21% reduction in 30-day hospital readmission No statistical test reported (Beales, 2009)31
Key Question 1c : Utilization of Services | Emergency Department Visits | 18.5% decrease, p=0.26 (Chang, 2009)33 2-year ED visit rate per 1000 Intervention group 1445 [n=474] vs. 1748 [n=477], p=0.03 (Counsell, 2007)35 10% fewer ED visits p=0.001 (De Jonge 2014)36 | 14.7% decrease in ED visits no statistical test reported (Beck 2009) 32 9.8% reduction ED visits, p=0.66 (Rosenberg, 2012)47 | 48% decrease ED Visits Pre: 166; post: 86 No statistical test reported (North, 2008)43
Key Question 1c : Utilization of Services | Nursing Home Admissions | —— | Patients with ≥1 SNF admissions Before enrollment 63 (35%) After enrollment 33 (18%), p=0.001 (Wajnberg, 2010)48 | ——
Key Question 1c : Utilization of Services | Nursing Home Days | 27% fewer SNF days, p=0.001 (De Jonge, 2014)36 No difference in SNF days p=0.68 (Edes 2014)37 | —— | 89% reduction in nursing home bed days No statistical test reported (Beales, 2009)31
Key Question 1c : Utilization of Services | Specialty Visits | 23% fewer specialty visits, p=0.001 (De Jonge, 2014)36 | Specialty Care Before: 1,100; after: 696 No statistical test reported (Beck, 2009) 32 | ——
Key Question 1c : Utilization of Services | Cost | Total Medicare costs during 2-year followup $44,455 vs. $50,977, p=0.001 Cases have lower cost for hospital, physician and SNF and higher costs for skilled home health care and hospice than controls. Overall cost differences significant only in cases vs. controls in the highest frailty category. (De Jonge 2014)36 Total average cost per patient 6 months before: $19,234 6 months during HBPC: $13,822 Total VA + Medicare costs per patient 28.1% reduction (95% CI, -29.2 to -27.1) p<0.001 13.4% absolute reduction in cost when compared to non-HBPC. Most significant cost saving in highest hierarchical condition category (Edes, 2014)37 | 22.7% increase in mean total charges No statistical test reported (Beck 2009) 32 Total costs: 12.1% higher for HBPC, p=0.005 (Hughes, 2000)39 Net revenue, $, median (IQR) 9,753 (7,945–14,684) 10,807 (8,174–15,832) p<0.001 Direct care costs, $, median (IQR) 3,245 (1,977–5,834) 3,699 (2,389–6,703) p<0.001 Indirect cost, $, median (IQR) 666.5 (399–1,199) 740 (466–1,355) p<0.001 Contribution to margin, $, median (IQR) 5,658 (3,308–8,408) 5,940 (3,543–9,034) p=0.34 Revenue and Costs increased resulting in a nonsignificant impact (Ornstein, 2011)45 | 24% decrease in mean total cost of care (from $38,000 to $29,000) No statistical test reported (Beales, 2009)31

ADL = activities of daily living, CI = confidence interval, ED = emergency department, HBPC = home-based primary care, HR-QOL = health-related quality of life, IQR = interquartile range, p = P-value, SNF = skilled nursing facility, VA = U.S. Department of Veterans Affairs, vs. = versus

a Rows of study results are organized by Key Question outcomes, the results are provided by study quality in columns from left to right for “Good”, “Fair”, and “Poor” quality rated results, and outcomes not provided are indicated by “——”.

#### Key Question 1a Impact on Health Outcomes

Few studies reported health outcomes or mortality (Key Question 1a), perhaps because the HBPC programs that were the subject of the included studies served patients who were predominately older, frail people with multiple chronic conditions and disabilities. Both studies that included mortality reported no significant difference between the HBPC group and a comparison group.35,36 Given the population it is not clear that reductions in mortality are possible, raising the possibility that no difference, that is no increase in mortality when care is provided at home, could be considered a positive outcome.

Physical function and symptoms were reported in two different studies. The multi-site RCT of HBPC in several VA medical centers found no significant difference in function between HBPC patients and usual care patients.39 This is one of the earlier studies of HBPC; one consideration is that the mean and median time in HBPC were 5.6 and 4.5 months, which may not be considered sufficient time to achieve improvements in functional outcomes. Another study in a non-VA HBPC program focused on decreased symptom burden; it reported that pain, anxiety, depression, and tiredness were reduced 3 weeks after HBPC enrollment and maintained at the lower levels at 12 weeks after enrollment.46 In this study 58 percent of patients with moderate to severe depressive symptoms and 45 percent with moderate to severe tiredness reported no symptoms at 3 weeks.

#### Key Question 1b Impact on Patient and Caregiver Experience

Three studies included measures of satisfaction or quality of life. In the two RCTs of HBPC, most caregiver outcomes were better for the HBPC group, and the patients experienced a statistically significant improvement in health-related quality of life.35,39 In a study that focused on caregiver burden and needs, caregivers of patients in a HBPC program reported a decrease in unmet needs 9 months after enrollment and a decrease in caregiver burden.46 Two poor-quality studies reported satisfaction at one point in time for HBPC patients.30,34

The only study we identified that explicitly raised the issue of potential harms examined whether HBPC had a negative impact on patient or caregiver experience. In patient and caregiver interviews from one VA center that supplemented quantitative analysis of HBPC costs with interviews (n=31), Edes et al. reported that none of the patient or caregivers had experienced any restriction on services since enrolling in HBPC.37

#### Key Question 1c Impact on Utilization of Services

HBPC impact on health care utilization and costs of services was the most frequently reported outcome in the research identified. Several studies reported the impact on hospitalizations (admissions, readmissions, and hospital days), emergency visits, nursing home admissions, or nursing home days. Studies also included costs of utilization. Fewer studies reported on the expected increase in primary care home visits. These results are in the evidence table (Appendix E).

Reducing hospitalization is an important and frequently stated priority for HBPC interventions based on the idea that high-quality primary care and the ability to address urgent needs should provide the means to avoid or at least reduce hospitalizations. Five high-quality studies33,35-38 reported on hospital admissions or hospital days. Four studies reported that hospitalization decreased with HBPC, while one study reported an increase (from 700 to 740 per 1000 patients) that was not statistically significant.35 One fair-quality study reported a 7.8 percent increase in hospitalizations but did not report a statistical test.32 The remaining fair- and poor-quality studies all reported reduction in hospitalization though some differences were not significant or did not include a statistical test. Based on a similar rationale, emergency visits are expected to be fewer for patients in HBPC programs. All six studies that examined emergency visits reported reductions ranging from 10 to 48 percent; however, one33 of the three good-quality studies33,35,36 reported that the reduction was not statistically significant (18.5% decrease, p=0.26), and the lower quality studies did not report actual numbers or a statistical test of difference.

Another intended benefit stated by HBPC programs is that it may reduce the need for skilled nursing facility (SNF) care. Three studies reported positive effects. One high-quality study reported 27 percent fewer SNF days (p=0.001).36 A fair-quality study found statistically significant fewer admissions,48 while a poor-quality article that was more of a program report than a research study reported an 89 percent reduction in nursing home days and no statistical test.31 Only one study analyzed nursing home admissions and reported fewer before HBPC enrollment than after,48 but this one small, moderate-quality study was not sufficient support for a conclusion in which we could have any confidence.

Costs were often measured as they relate to the utilization of care. In many studies of HBPC, the goal is to document whether the expected reduction in costs occurs, or at least that costs shift from hospital and emergency care to primary and home-based long-term care. Two high-quality studies examined costs, and both calculated that HBPC lowered costs significantly.36,37 Total Medicare costs were lower for HBPC participants than for matched controls in a Washington, D.C., HBPC program that is part of the Medstar Health Care System ($44,455 vs. $50,977, p=0.001).36 However, there was a significant reduction in overall cost only for the patients in the highest frailty category, and not in medium- or low-frailty groups. In another study, risk adjusted calculations and modeling for all VA HBPC patients nationwide compared projected costs without HBPC to actual costs and reported an average reduction of 28.1 percent in costs for 6 months of HBPC enrollment.37 This was a high-quality study, but one concern is that the comparison group used in calibrating the projected costs was a group of Veterans using long-term services and not a group matched to the HBPC participants. A poor-quality study reported a decrease in mean total cost but presented only the raw number with no information on potential confounding or statistical tests31 and one fair-quality study reported no significant impact to the organization's financial margin.45 Contrary to these findings, two studies with moderate risk of bias32,39 found substantial increases (22.7% and 12.1%) in charges and costs respectively.

Counsell et al.35 assessed recognition of geriatric conditions and used the Assessing Care of Vulnerable Elders (ACOVE) metrics to assess quality of care. With the exception of visual impairment, geriatric conditions were more commonly identified in the intervention patients (p-values all 0.01 or less). In general health care metrics, primary care visits occurred within 6 weeks of a hospital discharge for 83 percent of intervention patients versus 54 percent of controls (p<0.001), medication lists were provided, and advance care planning documents were more commonly addressed in the intervention patients (p<0.001).

### Key Question 2 How do the effects of home-based primary care interventions differ across patient characteristics and organizational characteristics?

#### Overview of Findings

- Patient characteristics: Four studies reported outcomes by patient subgroups. While the subgroups were defined differently in each study, the patients who were more frail, sicker, or at higher risk of negative outcomes benefited from HBPC more than those who were less frail or ill.
- Organizational characteristics: No studies were identified.

#### Key Question 2a Patient Characteristics

Four studies divided the patient population by severity of illness or frailty and examined results across subgroups:

- De Jonge 2014^36^ conducted a case-control study in which HBPC patients were matched to patients in usual care and found that total Medicare costs during the average 2-year followup period were significantly less for the HBPC patients ($44,455 vs. $50,977, p=0.01). When the participants were divided in to three groups based on a frailty index, the difference was significant only at the highest level of frailty (HBPC $58,689 vs. usual care $76,827; p<0.001).
- Edes 2014^37^ reviewed projected VA and Medicare costs for Veterans newly enrolled in HBPC and compared these projected costs to actual costs for Veterans enrolled and not enrolled in HBPC. Examining this result for patients divided by risk scores revealed that the magnitude and proportion of the reduction in costs were largest for the patients with the highest risk scores.
- Counsell 2007^35^ predefined a group of patients with a high probability of readmission over 4 years (p≥0.4) and found that both ED use and hospital admissions were significantly lower in this subgroup in the HBPC group than this subgroup in the usual care group during the second year of the intervention.
  ○ ED visits in the second year (848 [n=106] vs. 1314 [n=105], p=0.03)
  ○ Hospital admission rates (396 [n=106] vs. 705 [n=105], p=0.03)
  This differs from the overall study results in which the difference in hospital admissions was not significant.
- Hughes 2000^39^ divided patients based on whether they were terminally ill or not and found that results differed for these two groups. HBPC improved health-related quality of life in the terminally ill group and patient satisfaction in the group not terminally ill.

A consistent finding is that patients who are more frail, more ill, terminally ill, or in higher risk categories benefit more from HBPC interventions than patients with lower levels of illness severity or disability. However, this result must be tempered by the fact that the patient subgroups were defined differently in each of these studies. One used the JEN Frailty Index36, another relied on a risk adjustment model designed to project costs,37 the third estimated probability of hospital readmission,35 while the fourth study simply divided patients according to whether they had a terminal diagnosis or not.39

#### Key Question 2b Organizational Characteristics

We did not identify any studies that examined organizational characteristics. Nevertheless, these results suggested that HBPC interventions are most potent in reducing costs and acute care for the more frail populations of patients.

The evidence base was limited for Key Question 2. HBPC programs used different criteria for patient enrollment and thus cared for patients with mortality rates ranging from 7 percent35 to 40 percent.36

### Key Question 3 Which characteristics of home-based primary care interventions are associated with effectiveness?

#### Overview of Findings

- Combinations of components of HBPC interventions: There is wide variation in the services provided as part of HBPC interventions. In the evidence presently available there is not an apparent pattern or cluster of services associated with differences in outcomes. Most included assessment and coordination.
- Adding services to HBPC: Four studies examined the incremental impact of additional services to HBPC. Two studies found that combining palliative care and primary care visits increased the likelihood that patients would die at home (low strength of evidence). Two other studies added different additional services (insufficient evidence).

HBPC is delivered with a spectrum of services. At minimum, it requires a primary care provider willing to tackle the logistics and time investment of home-based care. Additionally, if the HBPC is team-based, it requires an organization with the capacity to assemble and support the team. HBPC can consist of a mosaic of services, many of which could be provided separately or in various combinations. Furthermore, the value added by a combination of services may be more than the sum of the valued added by each individual service. The result is that answering Key Question 3 about what characteristics of HBPC interventions are associated with effectiveness is challenging.

Given this, we attempted to address Key Question 3 in two ways: first by examining the components of the HBPC programs in the included studies and then by searching for and including any research that isolated a potential component of HBPC.

Table 5 lists each of the included studies and indicates which of several components are reported as part of the HBPC intervention. We grouped these components into categories. This approach was not based on any definitions or requirements for HBPC, and it is limited to the information that is available in the published study reports. If a service is or is not listed here for a specific study it does not mean that the service definitely was or was not provided, only that it was listed or not listed in the article.

Table 5 Components of home-based primary care reported in each study

Study | Personnel: Primary care provider | Personnel: Social workers | Personnel: Other providers | Planning: Assessment | Planning: Coordination | Planning: Team meetings | Planning: Referrals | Planning: Caregiver support | Planning: Afterhours and weekend coverage by HBPC (not ED, hospital providers) | Provided Care: Medication Management | Provided Care: Inpatient coordination | Provided Care: Education/coaching/Counseling | Provided Care: Medical tests (X-ray, blood, EKG) | Provided Care: Terminally ill care/palliative care
Aabom, 2006^26^ | Physician | | | | | | | | | | | | | ✓
Anetzberger, 2006^30^ | Physician, NP | | | ✓ | ✓ | | ✓ | ✓ | | ✓ | | ✓
Beales, 2009^31^ | Physician, NP or PA | ✓ | ✓ | ✓ | ✓ | | ✓
Beck, 2009^32,49^ | Geriatrician | ✓ | ✓ | ✓ | ✓ | ✓ | | | ✓ | | | | ✓
Chang, 2009^33^ | NP | | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | | ✓ | ✓
Cooper, 2007^34^ | NP or PA | ✓ | | ✓ | | ✓
Counsell, 2007^35^ | Physicians do not do visits; NP does | ✓ | | ✓ | ✓ | ✓
De Jonge, 2014^36^ | Physician, NP | ✓ | ✓ | | ✓ | ✓ | | | ✓ | | ✓
Edes, 2014^37^ | Physician, NP, or PA | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | | ✓
Edwards, 2014^38^ | Physician | ✓ | ✓ | ✓ | ✓ | ✓
Hughes, 2000^39^ | Physician | ✓ | ✓ | | ✓ | ✓ | ✓ | | ✓ | | ✓
Neergaard, 2009^37^ | Physician | | ✓ | | | | | | ✓ | | | | | ✓
Nichols, 2011^38^ | Physician, NP or PA | | ✓ | | | | | ✓ | | | | ✓
North, 2008^43^ | NP | ✓ | ✓ | | ✓ | ✓ | ✓
Ornstein, 2009^44^ | Physician, NP | ✓ | | ✓ | ✓ | | | ✓ | ✓
Ornstein, 2011^45^ | Physician, NP | | NP specifically for transition | ✓ | | | ✓ | ✓ | | ✓ | | ✓
Ornstein, 2013^46^ | Physician, NP | ✓ | ✓ | ✓ | ✓ | | ✓ | | ✓ | | ✓ | | | ✓
Rosenberg, 2012^47^ | Physician | | ✓ | ✓ | ✓ | ✓ | | | ✓ | | ✓ | | ✓
Wajnberg, 2010^48^ | Physician | | ✓ | ✓ | | | | | | | | | ✓

ED = emergency department, EKG = electrocardiogram, HBPC = home-based primary care, NP = nurse practitioner, physician = MD or DO; PA = physician assistant

✓= additional components of home-based primary care reported as included in the specific study.

In describing the components of HBPC across studies, Table 5 illustrates the variation across HBPC interventions. Our definition of HBPC does not include transitional care, preventive single visits, short-term care, or programs that provide care for a single condition. While we did require that a physician (MD or DO), nurse practitioner (NP), or physician assistant (PA) actually make home visits, we did not require specific components of HBPC to be provided or that a program call itself HBPC. As a result we included heterogeneous programs. We did include models where an additional physician may be involved or responsible for care but does not make home visits. For example, in the GRACE model35 a NP and a social worker make regular home visits to conduct assessments and provide care, but another primary care provider and a consulting geriatrician may be involved in care planning without making home visits. As the NP making the visits could provide care, we included this intervention and view it as a variation on the model that could be considered when assessing different approaches to HBPC.

Programs included a core of assessment and/or coordination and most programs included other health care providers in a team model in addition to the primary care provider. The content of HBPC interventions reported was variable. However, there were not obvious groupings of components of HBPC programs, making it difficult to compare outcomes across groups and make assertions about what combination of intervention components are associated with positive outcomes.

The second approach we used to answer this Key Question was to include studies that examined the incremental benefit of specific potential components of HBPC. We identified four studies that examined three different services that could be added to HBPC; caregiver support, transitional care, and palliative/end-of-life care.

- In a translational study, staff at 24 HBPC programs at VA medical centers in 15 states added an evidence-based caregiver support program, “Resources for Enhancing Alzheimer's Caregiver Health (REACH)”, to existing HBPC programs. Caregivers were evaluated at baseline and after 6 months. This study found statistically significant reductions in participant ratings of burden, depression, impact of depression on daily life, caregiver frustrations, and troubling dementia behaviors; there was no significant change in general health, health behaviors, safety, social support, and care giving difficulties.42
- Another study embedded a nurse practitioner-led transitional care program into a long-standing HBPC program. While qualitative data indicated that the staff was satisfied with the program, hospital length of stay and readmissions did not decline. Other factors resulted in patients with a higher (sicker) case mix, and overall the program did not significantly contribute to or subtract from the financial margin.45
- Two studies conducted in Denmark examined the relationship between palliative care and primary care home visits. The first study followed all cancer deaths in a region from 1997-1998 and found that primary care home visits were inversely associated with death in the hospital. As the number of home visits made by the primary care provider increased, the likelihood the patient would die in the hospital decreased.29 The second study was reported in two articles.40,41 This study relied on death records and administrative data to identify cancer patients who died in a 9-month study period and obtained data on primary care home visits and place of death. The authors surveyed the primary care physicians to obtain information about the physician's relationship with the patient and family and additional services provided. This study found that there was a strong association between primary care home visits and home death (prevalence ratio 4.3, 95% CI, 1.2 to 14.9) and that when physicians made three or more home visits the likelihood of home death increased significantly. Other variables related to the physician, such as extent of prior patient knowledge or whether they gave the patient their private phone number, were not significant. The involvement of a community health nurse in care was the only other significant factor in the increased likelihood of home death.

These studies are interesting and are an addition to the literature. However, they do not offer a head-to-head comparison of potential components or sufficient information to know if a component will be beneficial in the context of a different HBPC program.