# References

1 Howden LM, Meyer JA. Age and Sex Composition: 2010 United States Census Bureau. 2011. www.census.gov/prod/cen2010/briefs/c2010br-03.pdf.
2 Kinsella K, Wan H. An Aging World: 2008 U.S. Census Bureau. Washington, DC. 2009.
3 Federal Interagency Forum on Aging-Related Statistics. Older Americans 2012: Key Indicators of Well-Being. Federal Interagency Forum on Aging-Related Statistics. Washington, DC. Office USGP. 2012.
4 Salive ME. Multimorbidity in older adults. [Epub ahead of print]. Epidemiol Rev. 2013. Jan. 31. [pmid: 23372025].
5 Coleman K, Austin BT, Brach C, et al. Evidence on the Chronic Care Model in the new millennium. Health Aff (Millwood). Jan-Feb. 2009;28(1):75-85. [pmid: 19124857].
6 Kane RL, Preister R, Totten A. Meeting the Challenge of Chronic Ilness. Baltimore. Johns Hopkins University Press. 2005.
7 Epstein RM, Street RL Jr. The values and value of patient-centered care. Ann Fam Med. Mar-Apr. 2011;9(2):100-3. [pmid: 21403134].
8 Barry MJ, Edgman-Levitan S. Shared decision making--pinnacle of patient-centered care. N Engl J Med. Mar. 1. 2012;366(9):780-1. [pmid: 22375967].
9 Centers for Medicare & Medicaid Services. Independence at Home Demonstration. http://innovation.cms.gov/initiatives/independence-at-home/. April 3, 2014.
10 Priority Health. Michigan's first home-based primary care program launches statewide. 2013. www.priorityhealth.com/about-us/press-room/releases/2013/home-based-primary-care. April 2, 2014.
11 Rauch J. The hospital is no place for the elderly. The Atlantic. December. 2013.
12 Unwin BK, Tatum PE 3rd. House calls. Am Fam Physician. Apr. 15. 2011;83(8):925-38. [pmid: 21524032].
13 American Community Survey. United States Census Bureau. 2013. www.census.gov/acs/www/. March 31, 2015.
14 Centers for Medicare & Medicaid Services. Research, Statistics, Data & Systems. 2013. https://www.cms.gov/Research-Statistics-Data-and-Systems/Statistics-Trends-and-Reports/MedicareMedicaidStatSupp/2013.html. March 28, 2015.
15 Kinosian B, Edes T, Davis D, et al. Independence at Home (IAH) criteria Succesfully Targets Frail, Costly Veterans. J Am Geriatr Soc. 2015;63(S1):S128.
16 Rauch J. Opportunity Knocks at Home: How Home-Based Primary Care offers a Win-Win for US Health Care. Governancy Studies at Brookings. Washington, DC. 2013. www.brookings.edu/research/papers/2013/12/05-home-based-primary-care-win-win-for-us-health-care-rauch. July 7, 2015.
17 Veterans Health Administration. Home-Based Primary Care Program. Veterans Health Administration Transmittal Sheet. VHA Handbook No. 1141. 01. Washington, DC. Department of Veterans Affairs. 2007. www.va.gov/vhapublications/ViewPublication.asp?pub_ID=1534. August 11 2014.
18 Egan E. VA Home Based Primary Care Program: A Primer and Lessons for Medicare American Action Forum. Washington, D.C. American Action Forum. November. 1. 2012. http://americanactionforum.org/sites/default/files/VA%20HBPC%20Primer%20FINAL.pdf.
19 Bouman A, van Rossum E, Nelemans P, et al. Effects of intensive home visiting programs for older people with poor health status: a systematic review. BMC Health Serv Res. 2008;8:74. [pmid: 18387184].
20 Elkan R, Kendrick D, Dewey M, et al. Effectiveness of home based support for older people: systematic review and meta-analysis. BMJ. Sep. 29. 2001;323(7315):719-25. [pmid: 11576978].
21 Huss A, Stuck AE, Rubenstein LZ, et al. Multidimensional preventive home visit programs for community-dwelling older adults: a systematic review and meta-analysis of randomized controlled trials. J Gerontol A Biol Sci Med Sci. Mar. 2008;63(3):298-307. [pmid: 18375879].
22 Mayo-Wilson E, Grant S, Burton J, et al. Preventive home visits for mortality, morbidity, and institutionalization in older adults: a systematic review and meta-analysis. PloS One. 2014;9(3):e89257. [pmid: 24622676].
23 Meinck M, Lubke N, Lauterberg J, et al. Preventive home visits to the elderly: systematic review of available evidence. Gesundheitswesen. Nov. 2004;66(11):732-8. [pmid: 15562343].
24 Stall N, Nowaczynski M, Sinha SK. Systematic review of outcomes from home-based primary care programs for homebound older adults. J Am Geriatr Soc. Dec. 2014;62(12):2243-51. [pmid: 25371236].
25 Stuck AE, Egger M, Hammer A, et al. Home visits to prevent nursing home admission and functional decline in elderly people: systematic review and meta-regression analysis. JAMA. Feb. 27. 2002;287(8):1022-8. [pmid: 11866651].
26 van Haastregt JC, Diederiks JP, van Rossum E, et al. Effects of preventive home visits to elderly people living in the community: systematic review. BMJ. Mar. 18. 2000;320(7237):754-8. [pmid: 10720360].
27 Reuben DB, Tinetti ME. Goal-oriented patient care--an alternative health outcomes paradigm. N Engl J Med. Mar. 1. 2012;366(9):777-9. [pmid: 22375966].
28 Chang SM. The Agency for Healthcare Research and Quality (AHRQ) effective health care (EHC) program methods guide for comparative effectiveness reviews: keeping up-to-date in a rapidly evolving field. J Clin Epidemiol. Nov. 2011;64(11):1166-7. [pmid: 21959053].
29 Aabom B, Kragstrup J, Vondeling H, et al. Does persistent involvement by the GP improve palliative care at home for end-stage cancer patients?. Acad Nurs Palliat Med. Jul. 2006;20(5):507-12. [pmid: 16903404].
30 Anetzberger GJ, Stricklin ML, Gauntner D, et al. VNA HouseCalls of greater Cleveland, Ohio: development and pilot evaluation of a program for high-risk older adults offering primary medical care in the home. Home Health Care Serv Q. 2006;25(3-4):155-66. [pmid: 17062516].
31 Beales JL, Edes T. Veteran's Affairs Home Based Primary Care. Clin Geriatr Med. Feb. 2009;25(1):149-54. viii. ix. [pmid: 19217499].
32 Beck RA, Arizmendi A, Purnell C, et al. House calls for seniors: building and sustaining a model of care for homebound seniors. J Am Geriatr Soc. Jun. 2009;57(6):1103-9. [pmid: 19457154].
33 Chang C, Jackson SS, Bullman TA, et al. Impact of a home-based primary care program in an urban Veterans Affairs medical center. J Am Med Dir Assoc. Feb. 2009;10(2):133-7. [pmid: 19187882].
34 Cooper DF, Granadillo OR, Stacey CM. Home-based primary care: the care of the veteran at home. Home Healthc Nurse. May. 2007;25(5):315-22. [pmid: 17495561].
35 Counsell SR, Callahan CM, Clark DO, et al. Geriatric care management for low-income seniors: a randomized controlled trial. JAMA. Dec. 12. 2007;298(22):2623-33. [pmid: 18073358].
36 De Jonge KE, Jamshed N, Gilden D, et al. Effects of home-based primary care on Medicare costs in high-risk elders. J Am Geriatr Soc. Oct. 2014;62(10):1825-31. [pmid: 25039690].
37 Edes T, Kinosian B, Vuckovic NH, et al. Better access, quality, and cost for clinically complex veterans with home-based primary care. J Am Geriatr Soc. Oct. 2014;62(10):1954-61. [pmid: 25333529].
38 Edwards ST, Prentice JC, Simon SR, et al. Home-based primary care and the risk of ambulatory care-sensitive condition hospitalization among older veterans with diabetes mellitus. JAMA Intern Med. Nov. 2014;174(11):1796-803. [pmid: 25221986].
39 Hughes SL, Weaver FM, Giobbie-Hurder A, et al. Effectiveness of team-managed home-based primary care: a randomized multicenter trial. JAMA. Dec. 13. 2000;284(22):2877-85. [pmid: 11147984].
40 Neergaard MA, Vedsted P, Olesen F, et al. Associations between home death and GP involvement in palliative cancer care. Br J Gen Pract. Sep. 2009;59(566):671-7. [pmid: 19761666].
41 Neergaard MA, Vedsted P, Olesen F, et al. Associations between successful palliative trajectories, place of death and GP involvement. Scand J Prim Health Care. Sep. 2010;28(3):138-45. [pmid: 20698730].
42 Nichols LO, Martindale-Adams J, Burns R, et al. Translation of a dementia caregiver support program in a health care system--REACH VA. Arch Intern Med. Feb. 28. 2011;171(4):353-9. [pmid: 21357811].
43 North L, Kehm L, Bent K, et al. Can home-based primary care: cut costs?. Nurse Pract. Jul. 2008;33(7):39-44. [pmid: 18600171].
44 Ornstein K, Smith KL, Boal J. Understanding and improving the burden and unmet needs of informal caregivers of homebound patients enrolled in a home-based primary care program. J Appl Gerontol. 2009;28(4):482-503.
45 Ornstein K, Smith KL, Foer DH, et al. To the hospital and back home again: a nurse practitioner-based transitional care program for hospitalized homebound people. J Am Geriatr Soc. Mar. 2011;59(3):544-51. [pmid: 21391944].
46 Ornstein K, Wajnberg A, Kaye-Kauderer H, et al. Reduction in symptoms for homebound patients receiving home-based primary and palliative care. J Palliat Med. Sep. 2013;16(9):1048-54. [pmid: 23746230].
47 Rosenberg T. Acute hospital use, nursing home placement, and mortality in a frail community-dwelling cohort managed with Primary Integrated Interdisciplinary Elder Care at Home. J Am Geriatr Soc. Jul. 2012;60(7):1340-6. [pmid: 22694020].
48 Wajnberg A, Wang KH, Aniff M, et al. Hospitalizations and skilled nursing facility admissions before and after the implementation of a home-based primary care program. J Am Geriatr Soc. Jun. 2010;58(6):1144-7. [pmid: 20487075].
49 Beck AM, Kjaer S, Hansen BS, et al. Follow-up home visits with registered dietitians have a positive effect on the functional and nutritional status of geriatric medical patients after discharge: a randomized controlled trial. Clin Rehabil. Jun. 2013;27(6):483-93. [pmid: 23258932].
50 Boling PA, Leff B. Comprehensive longitudinal health care in the home for high-cost beneficiaries: a critical strategy for population health management. J Am Geriatr Soc. Oct. 2014;62(10):1974-6. [pmid: 25294407].
51 Leff B, Carlson CM, Saliba D, et al. The invisible homebound: setting quality-of-care standards for home-based primary and palliative care. Health Aff (Millwood). Jan. 2015;34(1):21-9. [pmid: 25561640].
52 McCauley K, Bradway C, Hirschman KB, et al. Studying nursing interventions in acutely ill, cognitively impaired older adults. Am J Nurs. Oct. 2014;114(10):44-52. [pmid: 25251126].
53 Moore GF, Audrey S, Barker M, et al. Process evaluation of complex interventions: Medical Research Council guidance. BMJ. 2015;350:h1258. [pmid: 25791983].
54 Mohler R, Kopke S, Meyer G. Criteria for Reporting the Development and Evaluation of Complex Interventions in healthcare: revised guideline (CReDECI 2). Trials. 2015;16:204. [pmid: 25935741].
55 Pinnock H, Epiphaniou E, Sheikh A, et al. Developing standards for reporting implementation studies of complex interventions (StaRI): a systematic review and e-Delphi. Implement Sci. 2015;10:42. [pmid: 25888928].
56 Edes T. Personal Communication. May. 14. 2015.
57 Centers for Medicare and Medicaid Services. CMS Releases the News: Independence at Home Improves Care and Lowers Cost. https://www.cms.gov/Newsroom/MediaReleaseDatabase/Press-releases/2015-Press-releases-items/2015-06-18.html. July 5, 2015.
58 Mathematica Policy Research. Evaluation of the Independence at Home Demonstration. www.mathematica-mpr.com/our-publications-and-findings/projects/evaluation-of-the-independence-at-home-demonstration. July 5, 2015.