# Methods

We performed the systematic review in accordance with the Evidence-based Practice Center (EPC) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”28 Input from experts was invited during protocol development; the final protocol is posted for the public on the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Web site: www.effectivehealthcare.ahrq.gov/. The protocol is also registered in the PROSPERO database under registration number: CRD42015016714. For detailed descriptions of the review methods, see Appendix A and the protocol on the AHRQ Effective Health Care Web site.

## Inclusion/Exclusion Criteria

The criteria for inclusion and exclusion of studies were designed to identify studies that answer the Key Questions. The criteria are based on the population, intervention, comparator, outcome, timing, and setting (PICOTS), which were developed as part of the topic refinement and included in the protocol for this review. The PICOTS are summarized in Table 2 and they were translated into our inclusion and exclusion criteria for the review. The included and excluded studies are listed in Appendix B and Appendix C, and the criteria are detailed in Appendix D.

Table 2 Inclusion and exclusion criteria

| Include | Exclude
Population | Adults with chronic illnesses or disabilities. | Children with special needs. Adults assessed for a single risk factor or condition. Healthy elderly.
Intervention(s) | Home-based primary care, as defined in Table 1. | Care models that do not include the four required characteristics. Examples of excluded care: preventive home visits, single visit home assessments, single purpose visits (fall risk assessments), care for a single condition, short-term home-based care, such as hospital at home programs.
Comparator(s) | Any other model of primary care. | Services that are not primary care.
Outcomes | Health care outcomes including mortality, morbidity and function. Patient and caregiver experience. Utilization of services and costs. | None
Timing | Longitudinal care, expected to continue until change in status. A specific time period for followup was not required for a study to be included. | Short-term, time-limited home-based care such as hospital at home programs.
Setting(s) | Patients' homes, broadly defined. (including private homes, group homes, adult foster care, and assisted living) United States or other developed countries. | Institutions such as nursing homes or prisons. Countries with economies and/or health care systems extremely different from those in the United States.
Study Design | Randomized controlled trials. High-quality observational studies, including comparative cohort studies and time series. Pre/post studies with or without a comparison group. Program reports and evaluations. | Descriptive studies. Case series or reports. Nonsystematic reviews. Journalistic reports.
Publication Type | Peer reviewed journals. Gray literature (if the study meets all other criteria). | Editorials or commentaries.

We included studies that evaluated the effects of home-based primary care (HBPC) interventions, including randomized controlled trials (RCTs), observational studies (comparative cohort studies and time series), pre/post studies with or without a comparison group, program reports, and evaluations. We included this broad range of study designs in order to obtain a comprehensive understanding of the current state of evidence about HBPC. Purely descriptive studies such as case series and case reports and journalist articles were excluded. Studies were not excluded based on a specific comparator or outcome; however, the comparators and approach to measuring the outcomes were considered as part of the assessment of the quality and risk of bias assessment of an individual study and influenced the assessment of the strength of evidence.

Systematic reviews were not included, but their included studies lists were used to identify individual studies to assess for inclusion in our review. English-language abstracts of non-English-language articles were reviewed and evaluated in terms of whether they would significantly add to the body of literature.

## Literature Identification and Data Analysis

A research librarian searched multiple electronic databases, including Ovid MEDLINE, CINAHL, ClinicalTrials.gov, and the Cochrane Database of Systematic Reviews for articles published between January 1995 and December 2014; searches were updated to include citations through May 2015. Additional studies were identified by reviewing reference lists of the included studies and systematic reviews and by requesting Scientific Information Packets and expert suggestions. Gray literature was identified by searching the New York Academy of Medicine gray literature database and the Web sites of organizations that may fund or produce research evaluating HBPC.

Two investigators reviewed each abstract and full-text article to determine inclusion eligibility. Any disagreements were resolved by consensus. A record of studies included is in Appendix B, and those excluded at the full-text level with reasons for exclusion are included in Appendix C. After studies were selected for inclusion, data were abstracted by one team member and verified for accuracy by a second team member. The evidence tables with the abstracted data are included in Appendix E.

Predefined criteria were used to assess the quality of individual RCTs and observational studies. A detailed description of the assessment is included in Appendix F. Individual studies were rated as “good,” “fair,” or “poor” by two investigators independently, with disagreements resolved by consensus. Studies rated “good” are considered to have low risk of bias and valid results. Studies rated “fair” are susceptible to some bias, though not enough to invalidate the results. Studies rated “poor” have significant flaws that imply biases of various types that may invalidate the results. We did not exclude studies rated as being poor in quality a priori, but poor-quality studies were considered to be less reliable than higher-quality studies when synthesizing the evidence.

Qualitative syntheses were conducted because the studies were too heterogeneous to create a meaningful combined estimate with meta-analyses.

The strength of evidence for each Key Question and outcome (Appendix G) was assessed using the criteria described in the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”28 Initial assessments were made by one researcher, then the entire team reviewed these and differences were resolved by consensus. This approach was possible given that this was a small review. The strength of evidence was assigned an overall grade of “high” (confident that the estimate of effect lies close to the true effect for this outcome), “moderate” (moderately confident that the estimate of effect lies close to the true effect for this outcome), “low” (limited confidence that the estimate of effect lies close to the true effect for this outcome), or “insufficient” (no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome).

Applicability considers the extent to which results from a study or a body of evidence can be used to answer the questions of interest. Variability in the studies or studies with unique attributes may limit the ability to generalize the results to other populations and settings. For this review we considered whether applicability is affected by the characteristics of the patient populations (e.g., demographic characteristics, reason for receiving home-based care, primary condition or disability, or presence of comorbidities) and the setting of the study (e.g., geographic location and practice context).

## Peer Review and Public Commentary

We invited specialists, including home-based primary care providers, health policy researchers, health care payers and providers, and patient caregiver/advocates, to provide peer review comments on the draft report. The AHRQ Task Order Officer and an Evidence-based Practice Center Associate Editor also suggested comments and provided editorial review. The draft report was posted on the AHRQ Web site for 4 weeks to acquire public comment. The disposition report with responses from the authors to the peer review comments and public comments will be posted after publication of the final report on the AHRQ Effective Health Care Web site.