# Introduction

## Background and Objectives

The aging of the population,1,2 the increasing number of people with chronic illnesses,3 and multimorbidity4 are important forces that are changing health care. One motivation for many health care reform efforts is that chronically ill, frail, and disabled patients may not be best served by the current common model of care,5,6 which is centered in office and hospital settings and frequently involves a disjointed array of providers. Another important motivation for reform is the focus on patient-centered care7 and on increasing patient and family engagement in health care decisions and management.8

High-quality primary care is comprehensive, serves as the patient entry point into the health care system, provides person-focused (rather than disease-oriented) care over time, addresses all but very uncommon or unusual conditions, and coordinates or integrates care across different types of providers and settings. Primary care is at the center of many health services delivery reform efforts, such as patient-centered medical home models (PCMH), precisely because it provides a usual source of care, encourages relationships with a provider, is more likely to include preventive services, can decrease the use of emergency departments for conditions that are not urgent, and may increase patient satisfaction.9-11

Home-based primary care (HBPC) interventions move the delivery of primary care from an office to the patient's home. HBPC programs have roots in the house call and community health outreach practices of earlier eras. In the past, house calls were a standard part of medical care and community health. Forty percent of physicians made house calls in the 1930s but this fell to less than 1 percent by the 1980s.12 While house calls have been making a comeback, particularly in geriatrics, today's house calls and home-based care are delivered in a very different health care system. Unlike the family doctor who made house calls, today most primary care providers do not see patients in multiple settings (e.g., in the office, the home, and the hospital) and HBPC primary care providers may or may not directly provide care outside the patient's home. For example, inpatient care may be primarily the responsibility of hospitalists while the HBPC team assures coordination and smooth transitions across sites of care. Many HBPC teams specialize in home-based care in the sense that they manage a panel of patients who are in these programs and have limited numbers of patients, if any, that they routinely see in an office.

HBPC as it currently exists is a model of health care delivery that combines home-based care for medical needs with intensive management and care coordination, and may also, but does not universally, include arranging or delivering long-term services and supports. HBPC interventions have been proposed as an alternative way of organizing and delivering care that may better address the needs, values, and preferences of chronically ill, frail, and physically or cognitively disabled patients who have difficulty accessing traditional office-based primary care or other models of care that require office visits. HBPC involves more than a rare house call; it is a comprehensive care delivery model that does not necessarily exclude a situation where a single primary care provider delivers most of the care; however, the more common approach is team-based care.

HBPC serves populations in whom complex chronic conditions and functional limitations intersect. Developing and evaluating HBPC interventions is important because the number of people who may benefit from this model of care is large and growing. The American Community Survey conducted by the U.S. Census Bureau estimated that in 2013, 15.4 percent of people in the United States over 65 years (more than 6.6 million people) had independent living difficulties, defined as difficulty with activities such as visiting a doctor's office or shopping without help because of a physical, mental, or emotional problem; 9.2 percent (over 3.9 million) had a cognitive difficulty; and 8.5 percent (over 3.6 million) had difficulty with self-care such as dressing, bathing, and eating.13 While the percentages are smaller, a similar number of adults 18 to 64 years old have functional difficulties (3.6%, equaling 7.1 million, have independent living difficulties; 1.9%, equaling 3.6 million, have a self-care difficulty).13 According to the Centers for Medicare & Medicaid Services (CMS), 3,459,600 people were served by Medicare home health in 2012, and the numbers have been increasing every year.14 Home health under the Medicare skilled home health care Part A benefit differs from HBPC in that it is usually for a shorter, defined period. An analysis of claims data for 2012 identified approximately 620,000 people in fee-for-service Medicare who received primary care in their home.15 Not everyone with a chronic illness or functional difficulty needs or wants help. Nevertheless, these numbers suggest that many people could benefit from an expansion of HBPC.

The specific reasons a patient may benefit from HBPC and the potential advantages vary. Functional impairments, costs, or other limitations may make transportation to doctors' offices or clinics challenging, or caregivers may not be available to accompany patients during normal office or clinic hours. In some situations, going to an office may be contraindicated. For example, patients with cognitive deficits may become confused or agitated in unfamiliar surroundings. Providers also obtain better insight into the patient's needs with a home visit, often finding environmental factors that are related to patient problems. Patients with complex needs may require frequent monitoring, intense management, or rapid followup that cannot be easily accommodated by an office-based provider. Patients at high risk may avoid complications from hospital care (e.g., certain infections, delirium) if hospitalizations can be prevented, averted, or shortened.

Potential benefits of HBPC include: (1) increased access to care for people who have difficulty traveling to outpatient medical offices or for whom going to a medical office is contraindicated—this could include access afterhours, weekends, or holidays, more frequent visits, and the ability to be seen sooner; (2) access that includes a range of services, including therapies, pharmacy, and medication management that have the potential to prevent or slow functional and cognitive decline; (3) better understanding of patient environments, needs, and constraints that can improve care and ultimately outcomes; (4) increased patient engagement, as a home visit can shift the focus of care more toward patient preferences; (5) decreased hospitalizations and urgent care use when acute incidents are prevented or addressed in the home; (6) better identification of and support for family caregivers; (7) increased patient and caregiver satisfaction; and (8) lower costs for Medicare and other payers. If all these benefits could be realized, HBPC would offer, as one analyst stated, “a win-win for U.S. health care”,16 referring to the potential opportunity to both reduce costs as well as improve quality of care and increase patient well-being.

HBPC was developed based on a house calls program at Mt. Sinai Medical Center in New York City and was implemented as a pilot model in the U.S. Department of Veterans Affairs (VA) more than 3 decades ago. It was designed to serve chronically ill veterans by providing effective primary care services as well as long-term care services in the home. The unique aspects of the model were related to its intention to provide “interdisciplinary care that is longitudinal and comprehensive rather than episodic and focused.”17 While the details can vary across the many different VA medical centers, today the VA HBPC program includes an interdisciplinary team that provides care in the home to veterans with complex needs for whom clinic-based care is difficult due to function or disease. Additionally, in many VA medical centers the model has expanded to include more mental health services and to formally facilitate collaboration with other services such as hospice. In non-VA settings, HBPC has developed based on elements of programs designed for people who are eligible for Medicaid and Medicare (frequently referred to as “dual-eligibles”), on the expansion of home and community-based long-term services and support programs, and on the expansion of physician house call programs.

Interest in HBPC is growing among the general public, health professionals in multiple disciplines, health care delivery organizations, and venture capital investors. This is reflected in current policy, practice, and research. HBPC is currently the subject of a major CMS demonstration project9 and even before this demonstration, an increasing number of public and private health systems and plans were beginning to offer HBPC.10 HBPC interventions have been the subject of articles in general publications11 as well as the topic of policy analyses.18 Research studies on HBPC have been summarized in seven systematic reviews.19-26 The increasing interest in HBPC models is also related to efforts to develop and implement new financing mechanisms and interdisciplinary team care as HBPC blurs boundaries between services, episodes, and roles. This level of interest suggests that HBPC programs are likely to continue to expand and to evolve, incorporating advances in communications, health information technology, and care management applications.

Important questions about the impact of HBPC limit its development, promotion, and expansion. Despite the extensive experience that some systems have had with HBPC, the benefits or harms of HBPC have remained poorly defined and documented. Studies of HBPC have been limited in several ways (e.g., single site, small-to-moderate sample sizes, variations in the HBPC intervention within and across studies, and studies spread over more than 2 decades during which the care and policy environments have changed).

The evidence base examining HBPC programs has expanded in recent years, yet challenges in synthesizing this literature reflect the challenges in primary research on HBPC. HBPC interventions are not standardized and often differ in terms of what care and services are offered, how frequently these services are available and used, the resources required to deliver these services, and the goals of the programs and providers. Research articles often do not provide sufficient descriptions of the interventions to allow nuanced analyses of how these differences might impact outcomes. There is marked variation in the prioritization and reporting of outcomes and a lack of clarity about which study designs and comparisons will provide the strongest, most useful evidence for future decisions about HBPC. Previous reviews have frequently highlighted this lack of detailed information about the intervention and outcomes as a weakness in the evidence base. Additionally, most studies provide little information about the comparison group, which is often simply described as “usual care”. Studies of HBPC span more than 20 years and have been conducted in several countries, thus it is likely that “usual care” has had different meanings. Moreover, HBPC interventions have been used to provide services to populations with different health risks, including severely disabled patients of all ages, elderly who would be nursing home eligible, and patients with complex care issues who may be less impaired. Some of these differences may be because patients can enter HBPC programs in different ways such as volunteer enrollment, as a recruitment based on a profile generated by a health plan, or referrals from different types of providers. Given the variation in populations, it is understandable that HBPC interventions have wide-ranging goals that span from preventing falls to providing palliative care.

Questions remain about which outcomes best match the different goals of different applications of HBPC and which outcomes are most important to different patients.27 The objectives of this review are to summarize the effects of HBPC interventions on a variety of outcomes and to examine how these effects vary by patient, organizational, and intervention characteristics. We examined the literature and included a broad range of outcomes, but with a narrower focus in terms of the population and the goals of the HBPC intervention (we excluded home visit programs that provide only prevention and well elderly outreach) than was used in some prior reviews, with the goal of analyzing this literature in the context of current policy issues.

## Scope and Key Questions

To clarify the scope and purpose of our review, we defined HBPC interventions as requiring the four characteristics described in Table 1. These defining characteristics underscore how HBPC interventions differ significantly from other innovative care models such as Hospital at Home (short term for acute need), Program of All-inclusive Care for the Elderly (PACE) (integrated primary and long-term care services, not usually home-based), and Patient-Centered Medical Homes (essentially outpatient, office-based), each of which contain some, but not all of these characteristics.

Table 1 Defining characteristics of home-based primary care models for this review

Required for This Review | Optional | Excluded
1. Visits by a primary care provider Visits by a physician, nurse practitioner, or physician assistant. | Additional visits Nurses, physical therapists, social workers, counselors, etc. | Other models that do not include primary care home visits. Telephone call care only or nurse (or other provider) care only.
2. Visits to a patient's home Home is defined as any noninstitutional setting where the patient resides. It can include private houses or apartments, adult homes, senior housing or assisted living. | Following patient across care settings In hospital management and short-term post-acute rehabilitation. | Patients in institutions Patients who live in nursing homes, prisons, or long-term care hospitals.
3. Longitudinal management The intention is to provide care for an indefinite period until admission to an institution, change in status, or death. | Not applicable. | Short term One-time home visits or assessments, hospital at home models in which care is provided for an acute need and the patient returns to previous primary care, or transitional care, for a short defined period (e.g., 30 to 90 days post-hospitalization, or 14 day after surgery).
4. Comprehensive primary care Includes medical care for, and the management of, chronic conditions and disabilities, preventive care, providing or arranging needed acute care and environmental assessments. | Inclusion of additional services such as mental health services, palliative care, long term services and supports or social services Assessment and management of serious mental illnesses including depression. Integration of palliative care or hospice with home-based primary care. | Single condition care or single topic risk assessments Fall risk assessments, programs that target a single condition such as congestive heart failure.

The analytic framework used to guide this report is shown below (Figure 1). The analytic framework illustrates the scope of the review, including the target population, interventions, comparators, and outcomes, and represents the interrelationships that are included in our Key Questions and that were examined in this review.

Figure 1 Analytic framework for home-based primary care interventions

KQ = Key Question

This figure is the Analytic Framework for Home-Based Primary Care Interventions for adults with chronic conditions and disabilities. The figure depicts the key questions within the context of the PICOTS described in the text in Table 2 on page 7 and Appendix A. In general, the figure illustrates how Home-Based Primary Care Interventions may result in outcomes such as Health Outcomes, Patient and Caregiver Experience or Utilization of Services. There are three Key Questions. Displayed for Key Question 1 there are three parts related to the following types of outcomes; a. Health Outcomes, b. Patient and Caregiver Experience c. Utilization of Services. Key Question 2 consists of how the effects of Home-Based Primary Care Interventions differ according to two types of factors; a. Patient Characteristics. and b. Organizational Characteristics. Key Question 3 examines intervention characteristics that are associated with effectiveness Harms are described as Adverse Effects of Intervention.

## Analytic Framework

A document containing the draft Key Questions was developed during Topic Refinement and was available for public comment via the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Web site from August 15, 2014, to September 05, 2014. The comments received helped us identify areas that required more explanation and reorganization in order to clarify our intentions for the systematic review.

The following are the Key Questions for this review.

Key Question 1. Among adults with chronic conditions that are serious or disabling, what are the effects (positive and negative) of HBPC interventions on:

a. Health outcomes
b. Patient and caregiver experience
c. Utilization of services

Key Question 2. How do the effects of HBPC interventions differ across:

a. Patient characteristics (including, but not limited to: reason for HBPC, type and number of diagnoses, level of physical and cognitive function, caregiver availability, and demographics)
b. Organizational characteristics (including, but not limited to: ownership organizational structure, payment structure, leadership, and staffing patterns of the practice or health system providing HBPC)

Key Question 3. Which characteristics of home-based primary care interventions are associated with effectiveness (including, but not limited to, use of teams, composition of teams, use of technology, frequency of visits, and types of visits/services)?