# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Bruce Kinosian, M.D.
  Associate Professor of Medicine, Division of General Internal Medicine
  Senior Fellow, Leonard Davis Institute of Health Economics
  Associate Scholar, Center for Clinical Epidemiology and Biostatistics
  University of Pennsylvania
  Philadelphia, PA
- Christine Mueller, Ph.D., R.N., FGSA, FAAN
  Associate Dean for Academic Programs
  Long Term Care Professor in Nursing
  School of Nursing
  University of Minnesota
  Minneapolis, MN
- Christine Ritchie, M.D., M.S.P.H., FACP
  Professor of Medicine
  University of California, San Francisco
  San Francisco, CA
- Robyn Stone, Dr.P.H.
  Senior Vice President, LeadingAge Center for Applied Research
  Executive Director, Center of Applied Research, LeadingAge
  Washington, DC