# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Christine Bishop, Ph.D.^*^
  * Provided input on draft report.
  Atran Professor of Labor Economics
  Schneider Institute for Health Policy
  Heller School of Social Policy and Management
  Brandeis University
  Waltham, MA
- Samuel Edwards, M.D., M.P.H.^*^
  Assistant Professor
  Oregon Health & Science University
  Staff Physician
  Veterans Affairs Portland Health Care System
  Portland, OR
- Alan Kronhaus, M.D.
  Co-Founder and CEO
  Doctors Making Housecalls
  Chapel Hill, NC
- Jay LaBine, M.D.
  Chief Medical Officer
  Priority Health
  Grand Rapids, MI
- Bruce Leff, M.D.^*^
  Co-Director, Elder House Call Program in the Division of Geriatric Care
  Professor of Medicine, Johns Hopkins University School of Medicine
  Baltimore, MD
- Helena Ross, L.C.S.W.^*^
  Social Work Program Coordinator
  Visiting Doctors Program
  Mount Sinai Hospital
  New York, NY
- Constance Row, L.F.A.C.H.E.
  Executive Director
  American Academy of Home Care Medicine
  Edgewood, MD
- Julia Zucco, Ph.D.^*^
  Social Science Research Analyst
  Independence at Home Demonstration
  Center for Medicare & Medicaid Innovation
  Centers for Medicare & Medicaid Services
  Baltimore, MD