# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Debra Bakerjian, Ph.D., M.S.N.
  Director for Nurse Practitioner and Physician Assistant Clinical Education and Practice
  Betty Moore School of Nursing
  University of California, Davis
  Davis, CA
- Jennifer Brown, M.S.
  Social Science Research Analyst
  Independence at Home Demonstration
  Center for Medicare & Medicaid Innovation
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Thomas Edes, M.D., M.S.
  Director of Geriatrics and Extended Care for Clinical Operations
  U.S. Department of Veterans Affairs
  Washington, DC
- Susan L. Hughes, D.S.W.
  Professor of Community Health Sciences
  Institute for Health Research and Policy
  Director, Center for Research on Health and Aging
  University of Illinois
  Chicago, IL
- Jay LaBine, M.D.
  Chief Medical Officer
  Priority Health
  Grand Rapids, MI
- Bruce Leff, M.D.^*^
  * Provided input on draft report.
  Professor of Medicine
  Co-Director, Elder House Call Program in the Division of Geriatric Medicine
  Professor of Medicine, Johns Hopkins University School of Medicine
  Baltimore, MD
- Joanne Lynn, M.D.
  Altarum Center for Elder Care and Advanced Illness
  Ann Arbor, MI
- Edward Ratner, M.D.
  Associate Professor of Medicine
  Medical Director
  Heartland Home Health Care and Hospice
  University of Minnesota
  Minneapolis, MN
- Albert Terrillion, Dr.P.H., Med., CPH
  Senior Director
  Clinical and Community Partnerships
  National Council on Aging
  Washington, DC
- Julia Zucco, Ph.D.^*^
  Social Science Research Analyst
  Independence at Home Demonstration
  Center for Medicare & Medicaid Innovation
  Centers for Medicare & Medicaid Services
  Baltimore, MD