# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Andrew Hamilton, M.L.S., M.S., for the literature searches; Leah Williams, B.S., for copy editing; Marcus E. Sharpe, Psy.D., Sandra Assasnik, M.A., Monica Daeges, B.A., and Elaine Graham, M.L.S., for assistance preparing the report; Marian McDonagh, Pharm.D., Associate Director, Pacific Northwest Evidence-based Practice Center; Christine Chang, M.D., M.P.H., Task Order Officer at the Agency for Healthcare Research and Quality; and our Associate Editor, Mary Butler, Ph.D., M.B.A.