# Discussion

HBPC increases access by providing a different route to health care for people who face barriers to obtaining outpatient primary care. To the extent that HBPC can improve access and not cause harm, it is successful. A common expectation is that HBPC can reduce avoidable use of hospital and emergency services by either preventing the need for higher levels of care or by providing care in in the patient's home. Aligning with these expectations, utilization was the most frequently studied outcome and it is the outcome for which we were able to draw the strongest conclusion. The evidence for each outcome is summarized in Table 6.

Table 6 Summary of evidence

Key Question | Outcome Number of Studies: Quality Rating | Summary of Findings^a^ | Strength of Evidence | Comments on Strength of Evidence
KQ1a. Health outcomes | Function 2 RCTs: 1 Good, 1 Fair 1 Obs: Poor | No significant difference In 2 RCTs no significant functional differences. 1 poor-quality observational study reported improvement | Low | Findings were inconsistent and the estimates were imprecise
KQ1a. Health outcomes | Symptoms 1 Obs: Fair | —— | Insufficient | 1 study (n=140) with relatively short-term followup (3 weeks)
KQ1a. Health outcomes | Mortality 1 RCT: Good 1 Obs: Good | No significant difference | Low | Study designs and measurement differ such that confidence in stability of findings is low
KQ1b. Patient and caregiver experience | Satisfaction 1 RCT: Fair 2 Obs: 2 Poor | Satisfaction results are positive | Low | Positive finding, but limited confidence in its stability given no comparison group in 2 lower-quality studies; higher satisfaction in one subgroup in the moderate-quality RCT
KQ1b. Patient and caregiver experience | SF-36 Quality of Life 2 RCTs: 1 good, 1 Fair | Significant improvement in some scales (4 of 8 in one study; 6 of 8 in another) | Low | Findings are inconsistent within and across studies with improvements in some scales and subgroups and not others
KQ1b. Patient and caregiver experience | Caregiver Burden/Needs 1 RCT: Fair 1 Obs: Poor | Significant improvements in caregiver outcomes including quality of life and reduced need for assistance | Low | Studies do not control for bias and other influences on results
KQ1b. Patient and caregiver experience | Negative unintended consequences/harms 1 Obs: Good | —— | Insufficient | Good-quality observational study reports lack of negative experience in small number (n=31) of subjects
KQ1c. Utilization of services | Hospitalization 2 RCTs: 1 Good, 1 Fair 9 Obs: 4 Good, 3 Fair, 2 Poor | Hospitalizations were reduced. 9 of 11 studies reported significant reductions in hospitalizations | Moderate | Findings are generally consistent across studies with different designs and 5 good-quality studies reporting reduced hospitalizations
KQ1c. Utilization of services | Hospital bed days 6 Obs: 2 Good, 2 Fair, 2 Poor | Numbers of days in hospital were reduced. 3 studies reported statistically significant reductions, 1 found no difference and 2 report reductions but do not provide a statistical test result | Moderate | Findings are comparatively precise and consistent
KQ1c. Utilization of services | Hospital Readmissions 1 RCT: Fair 2 Obs: 1 Fair, 1 Poor | Reductions were either not significant or not maintained over time | Low | Small differences and changes over time. Findings are inconsistent and imprecise
KQ1c. Utilization of services | Emergency Visits 1 RCT: Good 5 Obs: 2 Good, 2 Fair, 1 Poor | Emergency visits may be reduced 2 studies report reductions that are not significant, 4 found significant reductions | Low | Results are inconsistent and studies have important deficiencies in design
KQ1c. Utilization of services | Nursing Home Admissions 1 Obs: Fair | —— | Insufficient | Single study at 1 site with moderate sample (n=179)
KQ1c. Utilization of services | Nursing Home days 3 Obs: 2 Good, 1 Poor | Good-quality studies report inconsistent findings (1 significant reduction, 1 reduction (not tested), 1 no difference) | Insufficient | It is unclear if HBPC reduces nursing home days
KQ1c. Utilization of services | Specialty Visits 2 Obs: 1 Good, 1 Fair | Specialty visits may be reduced | Low | While results are consistent, they are limited to 2 studies with design limitations
KQ1c. Utilization of services | Costs 1 RCT: Fair 5 Obs: 2 Good, 2 Fair, 1 Poor | Recent high-quality studies document cost savings | Low | Overall findings are inconsistent. Findings of cost savings in high-quality studies and for sub groups of patients suggest cost saving are possible and ongoing studies may confirm this in the near future
KQ 2a. Patient characteristics | Severity of illness or frailty 2 RCTs: 1 Good, 1 Fair 2 Obs; 2 Good | Sicker or frailer patients are more likely to have positive outcomes. | Moderate | Studies used different approaches to defining subgroups of patients. Other studies may have been able to but did not report results by patient subgroups
KQ 2b. Organizational characteristics | | | Insufficient | No evidence identified
KQ 3. Characteristics of HBPC associated with effectiveness | Caregiver Support | —— | Insufficient | Single study in one site
KQ 3. Characteristics of HBPC associated with effectiveness | Transitional Care | —— | Insufficient | Single study in one site
KQ 3. Characteristics of HBPC associated with effectiveness | Primary care home visits and palliative care | Death seems more likely to occur at home when palliative care includes primary care home visits | Low | Two studies use place of death as outcome and have consistent though imprecise results

KQ = Key Question, Obs = observational study, NA = not applicable, RCT = randomized controlled trial

a Summary of findings not provided as evidence is insufficient to support a conclusion and are indicated by “——”.

In this review we found moderate-strength evidence supporting a reduction in utilization of hospital services with HBPC (Key Question 1c). This is an important finding as hospitalizations are expensive and often drive the overall cost of care. Additionally, some patients may prefer to avoid hospitalizations so this also could be an improvement in quality of life. When hospitalization cannot be avoided, HBPC may reduce the number of hospital days by assuring that adequate post-hospital care will be available (which may include medical interventions, nursing, and other therapies as needed). Low-strength evidence suggested possible reductions in emergency visits while the evidence about nursing home admissions and days was insufficient.

The findings related to costs were inconsistent. The more recent, high-quality studies36,37 are the ones that reported savings, suggesting that future studies may allow a stronger conclusion than our low-strength of evidence that HBPC reduces costs. This possibility is also supported by the fact that the early studies suggesting that HBPC increased rather than decreased costs had shorter intervention periods. It may be that patients did not receive HBPC for long enough to change their utilizations patterns or health status (e.g., in one randomized controlled trial [RCT] the average time in HBPC was under 5 months39). This difference may also be due to the fact that the more recent studies have measured costs using different methodologies that incorporate risk adjustment and include costs across payers. Additionally, while it may be important that HBPC substitutes for rather than supplements other services to offset the cost of the program, the expected or ideal pattern of change in utilization is not straightforward and may vary by the type of patient (e.g., it may be different for a patient nearing the end of life than a patient with a serious but stable condition).

The evidence about how patient characteristics are associated with HBPC effectiveness was limited in that studies investigating HBPC outcomes used different criteria to define the populations who received HBPC services. Despite this we found moderate strength of evidence that complex patients—those at highest risk of hospitalization (sicker) or most frail—have the most potential to benefit from HBPC. While some authors suggested or concluded that HBPC should be targeting the “right” patients, particularly to realize cost savings, other important outcomes were not analyzed by patient group. Without this information decisionmakers are not able to clearly understand how HBPC affects a range of outcomes for particular subpopulations and weigh the importance of different benefits for different patients.

Health outcomes were not frequently or comprehensively evaluated. Function and mortality did not differ significantly in HBPC versus usual care. While this means studies were not able to demonstrate improvement, either because there was no improvement or they were not able to detect it, it also means there was no documented decline in function or increase in death associated with HBPC. This could be viewed as a positive outcome in the sense that it does not appear that patient safety was compromised or that patients were harmed by being cared for with HBPC.

We found the strength of evidence supporting impact on satisfaction, quality of life, and caregiver outcomes to be low. It is notable that the studies that included these outcomes all report some positive effect, though often this was limited to a subgroup of patients or certain subscales of the measures. Only one study explicitly explored what could be considered an unintended consequence or harm and reported that patients and families did not experience any restriction of access to services.

We were unable to identify which specific combinations of program components were associated with success. While HBPC programs involved patient coordination and many used a team approach, the specifics of the intervention were not well defined in most reports. No study evaluated a spectrum of services, and the lack of clear definitions of interventions means it is not possible to precisely identify which components of the HBPC programs are beneficial. Future studies are needed to clarify which populations of patients benefit from HBPC and how to identify these patients. These may need to be pragmatic or adaptive studies that prospectively evaluate HBPC. Ideally, a clear means of characterizing frailty, functional and cognitive limitations, and diseases will be integrated into future HBPC programs. Our knowledge base will also benefit from clarity about the nature of the HBPC services provided in programs.

## Findings in Relationship to What Is Already Known

This review differs from several earlier reviews in that these reviews often included interventions that were one-time, that added home care to office-based primary care, or provided care for a limited period. Examples that we excluded but have been included in earlier reviews include preventive home visits, transitional care, hospital-at-home, or diversion programs that allowed acute care to be delivered in a patient's home.50-52 In fact, the mixing of these types of interventions and HBPC has been one of the problematic aspects of prior reviews. To avoid this we applied a strict definition of HBPC, requiring that primary care be delivered in the patient's home by a physician, NP, or PA and that the care be longitudinal and comprehensive. In our estimation this helped ensure we were comparing equivalent programs. However, we conducted a broad search and included studies that met these aspects of our criteria even if they did not self-identify specifically as HBPC.

One recently-published systematic review used a similar definition of HBPC but also limited the population to the homebound elderly and required that outcomes include hospital, emergency department (ED), or nursing home use.24 This review identified and summarized nine studies and concluded, as we did, that HBPC reduced hospitalization. While this review also reported a reduction in nursing-home admissions, we found the evidence to be insufficient. The difference is due to the fact that we included an additional, large high quality, recently published study that found no difference, resulting in inconsistent conclusions.

Our review builds and expands on these prior reviews in that it considered HBPC for adults of any age and included studies with any outcome. While the frail elderly are a logical target population for HBPC, the numbers of younger people with serious illness or temporary or permanent disabilities are growing, and it does not appear that the HBPC model needs to be restricted to frail elderly. Similarly, costs and utilization of services are important outcomes, but requiring these outcomes may lead to exclusion of evidence that could help decisionmakers consider costs and benefits in different ways.

## Applicability

Our summary and conclusions are applicable to patients with conditions or disabilities that make outpatient primary care difficult or less effective. While the most common type of patients provided HBPC have been homebound elderly, age is not the predominate factor and this model of care could serve patients of various ages, as has been demonstrated in the VA programs.

One consideration is that 8 of the 19 studies were conducted in VA medical centers, which has advantages and disadvantages for applicability. The Veterans served were predominately male, while the patients in other HBPC interventions were predominately female. In the nonveteran population, older male patients are more likely to have a living spouse and may have more access to informal care, although these demographics may be different for veterans. On the other hand the VA provides health services to veterans of all ages, including younger veterans with polytrauma or serious conditions like amyotrophic lateral sclerosis (ALS), making it possible that VA programs can be a model for how HBPC could serve a broader population than Medicare-eligible older adults.

In discussions of the goals of HBPC the target populations are often described as vulnerable, and this vulnerability typically refers to functional status and comorbidities. But vulnerability could be characterized in terms that add social and economic factors to medical and functional status. It seems likely HBPC might be particularly effective for patients who are vulnerable due to lack of social support. That said, HBPC may depend on the availability of a family caregiver. The available evidence does not allow us to say whether HBPC would be effective for these types of vulnerable patients or how their needs might differ.

Another major consideration about applicability relates to the organizations that provide HBPC interventions. Based on current evidence, we do not know what infrastructure is required to support HBPC. The included studies were conducted in the VA, in health plans, or in academic/health organization collaborations. This may reflect the need for both integrated services and the organizational capacity to support a program of care that can be resource intensive and differs in many ways from how office-based primary care is organized. As the authors of one of the included studies points out, “This setting provides ready referrals along with administrative and clerical supports…”30 While it is possible to make some very preliminary inferences about the types of organizations that could implement HBPC, the research does not address this issue directly; we identified no evidence about the impact of organizational characteristics. Community-based practices and even single primary care practices may be capable of providing HBPC, but they are less likely to be studied than programs in large systems. This may change as the results of the Centers for Medicare & Medicaid Services (CMS) Independence at Home (IAH) demonstration become available, as the participating organizations vary in structure and include free-standing, privately-held practices. Other health care reforms that also encourage collaboration and interdisciplinary approaches, such as patient-centered medical homes (PCMHs) and accountable care organizations, may lead to the development of organizational capacity to provide HBPC in a greater variety of practice settings. Evaluation studies of such more widespread HBPC implementation may produce research that provides a better understanding of the impact of organizational characteristics on HBPC effectiveness.

As discussed in the limitations section, the content of HBPC interventions is not standardized and is rarely reported in detail. This makes it difficult to estimate the extent to which the same results seen in any study or group of studies can be expected in a different situation in which the HBPC may provide or at least have access to different configurations of services.

## Implications

The results of this review indicate that HBPC, with its emphasis on coordinated, comprehensive primary care provided in patients' homes, has the potential to produce better outcomes for several types of patients, including patients with serious disabilities or multiple chronic conditions. Given the overall findings of this review that suggest that HBPC is a promising model of care, the expansion of HBPC and additional studies is reasonable and expected to continue.

This expansion is also likely to include standardizing core services and targeting HBPC programs to patients most likely to benefit. However, as one care model is not going to be appropriate for all patients and the exact combination of services or components probably should vary according to patient need, variability in HBPC should not necessarily be discouraged. Perhaps different of levels of intensity of HBPC or versions that address specific issues could be equally if not more effective.

## Limitations of the Review

Our review has several limitations. Bibliographic database indexing varies and HBPC is not a major indexing term in the databases we used. To address this limitation, we used combinations of other indexing terms and key word adjacencies. This may not have been sufficient if the intervention studied included the characteristics we required but did not use our included terms in reporting study results.

Additionally, while we did not exclude studies in languages other than English (though we required an English-language abstract), it is possible that in countries other than the United States, where health and social care are organized differently, other terms may have been used to describe research about similar models of health services delivery.

A review of published literature that focuses on comparative and quantitative studies cannot answer all questions about HBPC. Questions about the details of service delivery, the implementation of the programs, or the potential impact of patient, family, and provider attitudes and expectations might be best answered using qualitative research methods. However, reviewing or conducting qualitative research was outside the scope of this report.

## Limitations of the Evidence Base

The literature lacks detailed information on both the implementation process and context of HBPC interventions. Implementation is key to the success of an intervention and for this reason there is increasing attention paid to implementation science and process evaluation.53 The current literature does not directly address the possibility that an effective intervention can be rendered ineffective by how and where it is implemented.

The fact that HBPC interventions are not standardized, means that our comparisons and summaries across programs may be flawed. Perhaps the ability of HBPC to customize services to the patient is one of its strengths, but without agreement on core and optional services, it is possible that apples are being compared to oranges in some cases. This is a common challenge when evaluating complex interventions, and a challenge that ongoing efforts to establish reporting guidelines for complex interventions are working to address.54,55 While we attempted to document what services were part of the HBPC interventions in the included studies, our accuracy is limited by what was reported and our interpretation of these reports. Even in Veterans Affairs (VA) settings, there is likely more variation than might be expected. While HBPC programs in the VA are governed by national policy, there is considerable variation in staffing arrangements across the VA system. Some HBPC programs have nurse practitioners (NPs) or physician's assistants (PAs) who do nearly all of the diagnostic evaluation and management as well as most of the medication management; physicians provide oversight and make occasional home visits. Some programs have multiple physicians who routinely make home visits to every patient. But a limited number of sites do not have providers who make home visits, though the VA is working to establish the presence of providers in these locations.56

Given that we were not able to accurately assess the intensity, consistency, and quality of care provided, we cannot be sure whether in some cases the lack of HBPC benefits was related to the poor quality of the services. Quality metrics for home-based primary care are not widely used and are only in the developmental stages. One organization has developed a quality measurement framework, identified domains, and is currently field testing quality indicators, but that effort has its own challenges. For example, 14 of the 36 proposed quality standards could not be mapped to any existing quality standards in ambulatory and long-term care.51 The work in progress bodes well for the future, but the gaps between what is important in HBPC and quality measures currently in use in other settings underscore why it can be difficult to assess HBPC outcomes or determine which aspects of HBPC improve quality of care.

Finally, there is ambiguity in the literature surrounding the appropriateness and relative importance of potential outcomes for HBPC. Based on expert input about HBPC, we chose to report all the outcomes studied rather than limit the review to a specific subset of outcomes (e.g., only health services utilization or only clinical outcomes). However, one of the challenges related to outcomes for HBPC is that expecting improvement in many common clinical measures such as mortality or physical function may not be appropriate for the populations served by these programs. Particularly if HBPC is targeted to frail patients or those with high mortality rates, improvement may not be possible and a good outcome would be rates that are not higher than those in a similar population (i.e., that HBPC does not appear to be doing harm) as long as there were other benefits.

## Future Research

HBPC is a service delivery model that promises more efficient and effective care for patients with extensive needs in a format that may facilitate better quality of care and quality of life. Research on HBPC has increased over time in both volume and complexity; nevertheless, the level of the available knowledge does not match the growing interest in HBPC. In conducting this review and summarizing the available literature we identified areas in which future research could advance our understanding of HBPC and improve care of seriously ill or disabled patients.

However, in discussing topics for future research, it is important to acknowledge that a significant amount of new information will be available from the evaluation of the CMS IAH demonstration. Initial results released on June 18, 2015, report savings of more than 25 million in the first performance year with an estimated average savings of $3,070 per patient57 while all 17 participating practices improved on at least three of six measures of quality. This is the first release of data from a mixed methods evaluation that will document how HBPC practices approached improving outcomes; assess the impact on outcomes including health status, utilization of services, costs and savings, and patients and their caregiver's experiences with the program; and identify HBPC features that are the most important predictors of positive results.58 In our discussion of future research needs we consider which outstanding questions the IAH evaluation may address, but must acknowledge that this is speculation based on the information publicly available at the time this review was completed.

Based on our review, we offer the following considerations for planning future research in the advancing field of HBPC.

### Patient Selection

An important area for future research is refining the definition of which patient subpopulations will benefit most, that is, identifying for whom HBPC works, either by reducing costs or providing benefits or both. Ideally, research should include clear, replicable definitions of the target population for the HBPC intervention. Important knowledge could come from subgroup analyses of studies with less strict inclusion criteria or comparisons across HBPC implementations with different targeting criteria, although these approaches may require larger studies and more complex analyses. While the target populations are most frequently thought of in terms of severity or type of functional deficit or illness, the benefits of HBPC could also be studied across other patient characteristics, such as the type of housing (e.g., private single family home, apartment, assisted living, and adult foster care) and location (e.g., urban, suburban, rural, and proximity to other health services). It is also possible that HBPC could benefit different types of patients and targeting to restrict the program would not be desirable.

The IAH demonstration required that program patients have deficits in two or more activities of daily living (ADLs) and a hospitalization in the last year. These patients are quite ill and essentially nursing home eligible. The advantage of this approach is that these patients are also those likely to have high health costs, making it feasible that cost savings could be realized in a relatively short period of time even if providing HBPC requires significant resources (e.g., team care, travel time, 24/7 coverage).

What IAH will not reveal is whether or not there are other groups of patients who could benefit from variations on the HBPC model. Perhaps a less intensive version of HBPC provided to patients at risk of developing ADL deficits could also be effective in slowing decline. A version of HBPC might be appropriate for patients who do not have ADL deficits but who have serious mobility restrictions. HBPC should, as it often already does, serve both patients at the end of life and those with multiple conditions who are not terminally ill.

### Composition of HBPC Services

More research is needed that addresses which components of HBPC are linked to cost savings and benefits. As with other complex interventions, a typology could facilitate a better description and understanding of HBPC interventions. Being able to describe components and programs in a standardized way could encourage both systematic experimentation and better reporting about HBPC interventions and the care received by people in the comparison groups. The components could be specific services (e.g., types of visits) or they could be elements of the mission or organization structure. Categorizing these would allow us to ask and answer questions such as: Do social work visits improve outcomes? or, Do HBPC programs that explicitly have as a goal to keep patients out of the hospital have a greater impact on utilization? Another possibility that was not addressed in any of our included studies but that has been raised in policy discussions, the general press, and could be the subject of future study, is how technology could permit virtual visits to play a role in HBPC in the future.

Both the IAH evaluation and the efforts to develop quality measures for HBPC may improve our understanding of which components of HBPC contribute to improved outcomes. But this may be more complicated than simply identifying necessary program components. The results may suggest that different combinations of components can produce positive results. It is also possible that adding a particular component may benefit some people and not others (e.g., palliative care or mental health services) or that the timing and intensity of services may be as important as the combination of services. Given the number of important questions on this topic, it is likely that there will need to be significant research in this area in addition to the IAH evaluation.

### Study Designs

The study designs and quality of the studies we identified varied from program descriptions that included minimal data to randomized controlled trials (RCTs) and large, higher-quality observational studies. It is encouraging to note that the more recent studies were of higher quality and that researchers are applying more sophisticated approaches to the study of HBPC.

HBPC can be difficult to study for several reasons, making study design especially challenging. Randomization may be difficult given the patient population and the complexity of the intervention. Patients may need this type of care at a time when they are clinically unstable or after a medical crisis, making it difficult to determine whether improvement or decline would be expected and how long it might take for the intervention to improve outcomes. Given these challenges, observational studies that use sophisticated risk adjustment and modeling approaches to create valid comparisons are particularly important for future, high-quality research on HBPC. Also, longer studies are needed both to be sure that HBPC has had time to affect outcomes and to answer questions about whether the benefits persist and for how long.

More sophisticated study designs, such as randomization of sites within systems rolling out HBPC, staggered start designs that add HBPC to different sites at different times or observational studies that apply sophisticated analysis approaches to match patients or allow patients to serve as their own controls, could all add to our understanding of HBPC. In transitional care, which like HBPC is a complex intervention, more advanced study designs have followed the initial pilot and efficacy studies52 and this seems a logical next step for research on HBPC.

Studies must also be designed to evaluate implementation as well as effectiveness. These could be separate studies or objectives combined in a single study. In evaluations of service delivery, it can be difficult to disentangle the assessment of implementation from the study of effectiveness, but understanding what is important for successful implementation is critical. Without knowledge of factors contributing to successful implementation, the utility of proof of effectiveness is reduced. Implementation science and related methods continue to evolve and could be applied to this topic.

The IAH evaluation is an example of a nonrandomized study that uses advanced methods to address the selection bias and create appropriate comparisons. A key element of future research for IAH and other nonrandomized studies of HBPC will be sensitivity analyses and secondary analyses. Researchers should both test the sensitivity of the results to the selected methods used to create comparisons and explore what additional questions might be answered by further analyses.- Methods development related to complex interventions and implementation research could both be useful in increasing our understanding of HBPC.

### Outcomes

Utilization of services and costs may be key to feasibility, but the ultimate goal of any care model should be to improve the health and well-being of patients. None of the studies we identified asserted that they measured what was most important to HBPC patients. An effort to identify and use patient-centered outcomes specific to HBPC could lead to improvements in the relevance of future research.

The IAH demonstration evaluation plan includes patient and caregiver experiences with the program as outcomes to be studied. This is a step in the right direction. An important complementary effort would be to understand how patients and family caregivers prioritize clinical and functional outcomes. However, if HBPC serves different types of patients (e.g., patients on hospice at home and patients who are not terminally ill) it is also necessary to consider whether the outcomes and priorities differ for these different groups.

As HBPC expands, the number of evaluations is likely to increase. Developing a core set of outcomes (like a core set of quality measures currently under development51 discussed in Limitations in the Literature Base above) and encouraging their measurement in future research would facilitate comparisons across individual studies as well as potential future meta-analyses. These may need to be expanded to include outcomes specific to subgroups of patients, such as those at the end of life. Other important questions related to outcomes are: how quickly HBPC should be expected to have an impact on outcomes such as hospitalizations and ED use? and can changes in utilization be expected to continue to decrease, or should they stabilize as the program matures?

### Context

Ultimately the research on individual HBPC interventions should also advance our understanding of how to position HBPC in the larger health care system and the continuum of services. It is possible the HBPC could complement other care models, replace office-based care at certain times in a patient's trajectory, or be integrated into a package of comprehensive service. While we did consider the characteristics of the organizations providing HBPC, issues associated with how HBPC could fit with other models of primary care, long term services and support, or integrated models was outside the scope of this review and they were not directly addressed.

Our more narrow questions leads, nevertheless, to research (and policy) questions about when HBPC should be considered for different types of patients at different times in their illness or disability trajectory. It also raises questions about the comparative effectiveness of primary care in different settings (e.g., office, home, adult day health, assisted living, and nursing facility), how research might attempt to isolate the value of HBPC, and if HBPC should always be strictly defined as a separate service, incorporated into hybrid services, or if some patients should be discharged from HBPC if their condition improves. For example, if the patient is cared for by several home care physicians and does not establish a relationship with one, is HBPC more effective than office-based care where this relationship exists? Or could a model be created that adjusts the site of care as needed (e.g., home visits for assessment, urgent need, when transportation is not possible, and some office visits for planned, routine care).

Organization of service delivery and payment for services are intertwined. Several different financing mechanisms currently exist for services like HBPC, and new payment structures are an important part of health reform. How these may or may not impact the incentives for HBPC is another question related to the larger context.