# Conclusions

Home-based primary care (HBPC) is a promising model of care delivery for patients who may not be best served by the combination of outpatient and hospital care that predominates in our current system. Current research evidence is generally positive, providing moderate evidence that HBPC reduces utilization of inpatient care, and providing low strength evidence that it reduces utilization of other health services or improves clinical outcomes and patient and caregiver experiences. A small number studies reported results by patient subgroups; however, it appears that higher risk patients are likely to benefit from HBPC. We were not able to identify any research that directly examined organizational characteristics of health systems, health plans, or practices and how those characteristics might influence the impact of HBPC. While we documented the components of HBPC programs that have been the subject of study and we searched for studies that examined specific services (e.g., caregiver support), there is still insufficient evidence on which to base conclusions about the impact of different individual or combinations of services in HBPC.

The more recent studies of HBPC included larger sample sizes and comparison groups, and they incorporated more complex designs and analyses; however, the body of evidence is still comparatively small. When its results are released, the Centers for Medicare & Medicaid Services (CMS) Independence at Home (IAH) demonstration is likely to provide substantial new evidence about the benefits of HBPC for patients with significant functional deficits who would be nursing home eligible. Additional future research is needed that focuses on the content and organizational context of HBPC interventions so that differences can be identified and the experiences replicated or improved on by others. Research is also needed about what subgroups of patients benefit most from HBPC and how HBPC can be best used in the continuum of care for different types of patients.