# Strength of Evidence

Table G-1 Strength of evidence by outcome

Key Question Outcome | Number of Studies | Study Limitations (High, Medium, Low) | Directness (Direct, Indirect) | Consistency (Consistent, Inconsistent, Unknown) | Precision (Precise, Imprecise) | Reporting Bias (Suspected or undetected) | Strength of Evidence/Grade (High, Moderate, Low, Insufficient)
Key Question 1: Among adults with chronic conditions that are serious or disabling, what are the effects (positive and negative) of home-based primary care interventions on:
Health outcomes
Function | 3 | High | Direct | Inconsistent | Imprecise | Undetected | Low
Symptoms | 1 | Medium | Direct | Unknown | Imprecise | Undetected | Insufficient
Mortality | 2 | Low | Direct | Inconsistent | Imprecise | Undetected | Low
Patient and caregiver experience
Satisfaction | 3 | High | Direct | Consistent | Imprecise | Undetected | Low
SF-36/Quality of Life | 2 | Medium | Direct | Inconsistent | Imprecise | Undetected | Low
Caregiver Burden/Needs | 2 | High | Direct | Consistent | Imprecise | Undetected | Low
Utilization of services
Hospitalization | 11 | Medium | Direct | Consistent | Precise | Undetected | Moderate
Hospital Bed Days | 6 | Medium | Direct | Consistent | Precise | Undetected | Moderate
Hospital Readmissions | 3 | High | Direct | Inconsistent | Imprecise | Undetected | Low
Emergency Department | 6 | Medium | Direct | Inconsistent | Precise | Undetected | Low
Nursing Home Admissions | 1 | Medium | Direct | Unknown | Precise | Undetected | Insufficient
Nursing Home Days | 3 | Medium | Direct | Inconsistent | Precise | Undetected | Insufficient
Specialty Visits | 2 | Medium | Direct | Consistent | Imprecise | Undetected | Low
Costs | 6 | Medium | Indirect | Consistent | Imprecise | Undetected | Low
Negative unintended consequences/harms | 1 | High | Indirect | Unknown | Imprecise | Undetected | Insufficient
Key Question 2: How do the effects of home-based primary care interventions differ across:
Patient characteristics: severity of illness or frailty | 4 | Low | Direct | Consistent | Precise | Suspected | Moderate
Organizational characteristics | 0 | – | – | – | – | – | Insufficient
Key Question 3: Which characteristics of home-based primary care interventions are associated with effectiveness?
Caregiver support | 1 | Medium | Direct | Unknown | Precise | Undetected | Insufficient
Transitional care | 1 | Medium | Direct | Unknown | Precise | Undetected | Insufficient
Primary care home visits and palliative care at end of life | 2 | Medium | Indirect | Consistent | Imprecise | Undetected | Low
Others program components | 0 | – | – | – | – | – | Insufficient