# Quality Rating

Table F-1 Randomized controlled trials quality rating

Author, Year | Was the randomization method adequate? | Was the allocation concealment adequate? | Were groups similar at baseline or did the analysis control for any important baseline differences? | Were outcome assessors blinded to the patient group? Or are primary outcome measures unlikely to be biased? | Did the study rule out or control for impact from unintended exposures or concurrent interventions that might bias results? | Are there no concerns about bias due to attrition? Where comparable groups maintained? | Was fidelity to the intervention adequate? | Were valid and reliable measures of outcomes and confounders used and implemented consistently across all study participants/groups? | Was intention to treat analysis used? Was the method for handling missing data appropriate? | Were the potential outcomes prespecified and were all the prespecified outcomes reported? | Funding Source | External Validity | Quality Rating
Hughes, 2000 | NR | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | Department of Veterans Affairs | VA, predominately male population | Fair
Counsell, 2007 | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Grant: R01 AG20175 from the National Institute on Aging, National Institutes of Health | | Good

Please see Appendix B. Included Studies for full study references.

Table F-2 Observational studies quality rating

Author, Year | Was the selection of comparison groups or time periods adequate? Were inclusion and exclusion criteria applied uniformly across groups or time periods? | Were groups similar at baseline or did the analysis control for any important baseline differences? | Were outcome assessors blinded to the patient group? Or are primary outcome measures unlikely to be biased? | Did the study rule out or control for impact from unintended exposures or concurrent interventions that might bias results? | Are there no concerns about bias due to attrition? Where comparable groups maintained? | Was fidelity to the intervention adequate? | Were valid and reliable measures of outcomes and confounders used and implemented consistently across all study participants/groups? | Was intention to treat analysis used? Was the method for handling missing data appropriate? | Were the potential outcomes prespecified and were all the prespecified outcomes reported? | Funding Source | External Validity/Applicability Considerations | Quality Rating
Aabom, 2006 | Yes | Yes | Yes | No | NA (retrospective) | Yes | Yes | Unclear | Yes | Health Insurance Foundation, Danish Research Foundation for General Practice, Danish College of General Practitioners' Research Scholarship | Cancer patients from one region of Demark in a registry | Fair
Anetzberger, 2006 | Unclear | NA | No | No | No | Unclear | Yes | No | Yes | Grants from the Abington, Bruening, Cleveland, Saint Luke's, and Sisters of Charities Foundations. | Pilot project by one agency in Cleveland, OH | Poor
Beales, 2009 | Yes | Yes | Yes | No | No | Unclear | Unclear | Unclear | Unclear | Department of Veterans Affairs | VA, predominately male population | Poor
Beck, 2009 | Yes | No | Yes | No | No | Yes | Yes | No | Yes | National Institute on Aging awards K24-AG026770-01 and P30AG024967 | One program in a comprehensive academic health center senior care program | Fair
Chang, 2009 | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Department of Veterans Affairs | VA, predominately male population, single VA Medical Center | Good
Cooper, 2007 | Yes | Yes | Yes | No | Yes | Unclear | Unclear | Unclear | Yes | VHA | VA, predominately male population | Poor
De Jonge, 2014 | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Deerbrook Charitable Trust | VA, predominately male population | Good
Edes, 2014 | Yes | Yes | Yes | No | Yes | Unclear | Yes | Yes | Yes | Geriatrics & Extended Care, Office of Clinical Operations & Management, Veterans Health Administration; Intel Corporation; and the Memphis VA Medical Center | VA, predominately male population | Good
Edwards, 2014 | Yes | No | Yes | No | Yes | Unclear | Yes | NA | Yes | Department of Veterans Affairs | VA, predominately male population | Good
Neergaard, 2009 Neergaard, 2010 | Yes | Yes | Yes | No | No 63.2% response rate | Unclear | Yes | NA | Yes | Aarhus County Research fund for Clinical Development and Research in General Practice and Danish National Research Foundation for Primary care | Cancer patients in a single county in Denmark | Fair
Nichols, 2011 | Yes | NA | No | No | No | Yes | Yes | No | Yes | VA Patient Care Services | VA, predominately male population; multiple VA sites | Fair
North, 2008 | Yes | Yes | Yes | No | No | Unclear | Yes | Unclear | No | Department of Veterans Affairs | VA, predominately male population, single VA Medical Center | Poor
Ornstein, 2009 | Yes | NA | No | No | No | Yes | Yes | NA | Yes | NR | Single, large HPBC program in an urban area | Poor
Ornstein, 2011 | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Unclear | Yes | Fan Fox and Leslie R. Samuels Foundation | Single, large HPBC program in an urban area | Fair
Ornstein, 2013 | Yes | NA | No | No | No | Yes | Yes | No | Yes | Y.C. Ho/Helen and Michael Chiang Foundation | Single, large HPBC program in an urban area | Fair
Rosenberg, 2012 | Yes | NA | Yes | No | No | Yes | Yes | Unclear | Yes | Publically funded by the provincial government, BC and Victoria, Canada | Single program in Victoria, BC | Fair
Wanjberg, 2010 | Yes | NA | Yes | No | No | Yes | Yes | Unclear | Yes | No sponsor | Single, large HPBC program in an urban area | Fair

Please see Appendix B. Included Studies for full study references.