# Evidence Table

See Appendix B for the reference list for Appendix E.

Table E-1 Evidence table for home-based primary care interventions