# Included and Excluded Studies Criteria

## Full-Text Paper Inclusion/Exclusion Codes: Reasons for paper inclusion or exclusion

Inclusion:
1 = | Paper included as evidence (see Appendix A for inclusion criteria)
Exclusion:
2 = | Background paper only, no data for evidence
3 = | Discussion paper only (clinical subgroups, see above), no data for evidence
4 = | Discussion paper only (demographic subgroups, see above), no data for evidence
5 = | Wrong population (children and adolescents, patients with single conditions, healthy people receiving only preventive or assessment home visits)
6 = | Wrong intervention (does not meet criteria specified in Table 1), examples: Hospital at Home, PACE, Patient-Centered Medical Home (PCMH), postsurgery care, visits by (RN, LPN social workers only )
7 = | Wrong outcomes (not listed above)
8 = | Wrong study design (case reports, descriptive study, or design not sufficiently described)
9 = | Wrong publication type (opinions, letters to the editor, conference proceedings, abstract only)
10 = | Not English language but otherwise relevant^*^
11 = | Not human population
12 = | Inadequate care duration - short-term, time-limited home-based care, one-time visits
13 = | Study published before 1995
14 = | Systematic review not meeting requirements (wrong study designs included, no quality rating, nonsystematic reviews)
15 = | Inadequate sample size (n<20)
16 = | Primary care intervention, but no provider home visits

* NOTE: If foreign language but possibly relevant, code as 10. If foreign language and not included for another reason, use exclusion code for the other reason)