# Excluded Studies

Key to Excluded Study Reasons:

2 = | Background
3 = | Discussion paper only (clinical subgroups)
4 = | Discussion paper only (demographic subgroups)
5 = | Wrong population
6 = | Wrong intervention
7 = | Wrong outcome
8 = | Wrong study design
9 = | Wrong publication type
10 = | Not English language but otherwise relevant
11 = | Not human population
12 = | Inadequate care duration
13 = | Study published before 1995
14 = | Systematic review not meeting requirements
15 = | Inadequate sample size (n<20)
16 = | Primary care intervention, but no provider home visits

1 Abarshi E, Echteld M, Van den Block L, Donker G, Deliens L, Onwuteaka-Philipsen B. Transitions between care settings at the end of life in the Netherlands: results from a nationwide study. Palliat Med. 2010;24(2):166-174. Exclusion code: 6. [pmid: 20007818].
2 Amruso NA, O'Neal ML. Pharmacist and physician collaboration in the patient's home. Ann Pharmacother. 2004;38(6):1048-1052. Exclusion code: 6. [pmid: 15113983].
3 Auer P, Nirenberg A. Nurse practitioner home-based primary care: a model for the care of frail elders. Clinical Scholars Review. 2008;1(1):33-39. PMID: None. Exclusion code: 2.
4 Avlund K, Jepsen E, Vass M, Lundemark H. Effects of comprehensive follow-up home visits after hospitalization on functional ability and readmissions among old patients. A randomized controlled study. Scand J Occup Ther. 2002;9(1):17-22. PMID: None. Exclusion code: 6.
5 Avlund K, Vass M, Kvist K, Hendriksen C, Keiding N. Educational intervention toward preventive home visitors reduced functional decline in community-living older women. J Clin Epidemiol. 2007;60(9):954-962. Exclusion code: 16. [pmid: 17689812].
6 Baldwin G. Home sweet medical home. Growing numbers of primary care practices are embracing the I.T.-intensive model of care delivery. Health Data Manag. 2013;21(1):12-16. Exclusion code: 2. [pmid: 23373167].
7 Banerjee S, Shamash K, Macdonald AJ, Mann AH. Randomised controlled trial of effect of intervention by psychogeriatric team on depression in frail elderly people at home. BMJ. 1996;313(7064):1058-1061. Exclusion code: 6. [pmid: 8898601].
8 Beaussier M, Vons C. Post-hospital home care after ambulatory surgery. Presse Med. 2014;43(3):305-308. Exclusion code: 6. [pmid: 24525305].
9 Beck AM, Kjaer S, Hansen BS, Storm RL, Thal-Jantzen K. Study protocol: follow-up home visits with nutrition: a randomised controlled trial. BMC Geriatr. 2011;11:90. Exclusion code: 2. [pmid: 22204420].
10 Bholat MA, Ray L, Brensilver M, Ling K, Shoptaw S. Integration of behavioral medicine in primary care. Prim Care. 2012;39(4):605-614. Exclusion code: 2. [pmid: 23148953].
11 Birk S. Making the transition to medical homes: from primary care to patient-centered care. Healthc Exec. 2011;26(2):26-28. 30. 22. 34. Exclusion code: 2. [pmid: 21404807].
12 Biscione FM, Szuster DA, Drumond Ede F, et al. Home care effectiveness assessment in a health maintenance organization in Belo Horizonte, Minas Gerais State, Brazil. Cad Saude Publica. Suppl 1. 2013;29:S73-80. Exclusion code: 10. [pmid: 25402253].
13 Bitton A. Who is on the home team? Redefining the relationship between primary and specialty care in the patient-centered medical home. Med Care. 2011;49(1):1-3. Exclusion code: 2. [pmid: 21164324].
14 Bobrie G, Chatellier G, Genes N, et al. Cardiovascular prognosis of “masked hypertension” detected by blood pressure self-measurement in elderly treated hypertensive patients. JAMA. 2004;291(11):1342-1349. Exclusion code: 2. [pmid: 15026401].
15 Boling PA, Leff B. Comprehensive longitudinal health care in the home for high-cost beneficiaries: a critical strategy for population health management. J Am Geriatr Soc. 2014;62(10):1974-1976. Exclusion code: 9. [pmid: 25294407].
16 Boult C, Reider L, Leff B, et al. The effect of guided care teams on the use of health services: results from a cluster-randomized controlled trial. Arch Intern Med. 2011;171(5):460-466. Exclusion code: 16. [pmid: 21403043].
17 Bouman A, van Rossum E, Evers S, Ambergen T, Kempen G, Knipschild P. Effects on health care use and associated cost of a home visiting program for older people with poor health status: a randomized clinical trial in the Netherlands. J Gerontol A Biol Sci Med Sci. 2008;63(3):291-297. Exclusion code: 6. [pmid: 18375878].
18 Bouman A, van Rossum E, Nelemans P, Kempen GI, Knipschild P. Effects of intensive home visiting programs for older people with poor health status: a systematic review. BMC Health Serv Res. 2008;8:74. Exclusion code: 16. [pmid: 18387184].
19 Bourdi E, Breton C, Plancon S. Medico-social decisions: aging and staying at home. Soins Gerontol. Gerontologie. 1999;(20):36-39. Exclusion code: 6. [pmid: 10808943].
20 Bowman MA, Neale AV. Policy and financing in family medicine and the medical home. J Am Board Fam Med. 2010;23(3):277-279. Exclusion code: 6. [pmid: 20453171].
21 Bowman MA, Neale AV, Lupo P. The medical home, health services, and clinical family medicine research. J Am Board Fam Med. 2008;21(5):367-369. Exclusion code: 6. [pmid: 18772289].
22 Boyd CM, Shadmi E, Conwell LJ, et al. A pilot test of the effect of guided care on the quality of primary care experiences for multimorbid older adults. J Gen Intern Med. 2008;23(5):536-542. Exclusion code: 16. [pmid: 18266045].
23 Boyd ML, Fisher B, Davidson AW, Neilsen CA. Community-based case management for chronically ill older adults. Nurs Manage. 1996;27(11):31-32. Exclusion code: 6. [pmid: 8954445].
24 Brassard A. NPs in home care. Nurs Spectrum. 2013;25(2):8-8. PMID: None. Exclusion code: 2.
25 Brown D, McWilliam C, Ward-Griffin C. Client-centred empowering partnering in nursing. J Adv Nurs. 2006;53(2):160-168. Exclusion code: 6. [pmid: 16422714].
26 Burrell C. One payer's attempt to spur primary care doctors to form new medical homes. Interview by Susan Dentzer. Health Aff (Millwood). 2012;31(2):341-349. Exclusion code: 9. [pmid: 22416341].
27 Butcher L. A different kind of medical home. Hosp Health Netw. 2012;86(12):42-45. 41. Exclusion code: 9. [pmid: 23330323].
28 Callahan CM, Boustani MA, Schmid AA, et al. Alzheimer's disease multiple intervention trial (ADMIT): study protocol for a randomized controlled clinical trial. Trials. 2012;13:92. Exclusion code: 9. [pmid: 22737979].
29 Callahan CM, Boustani MA, Weiner M, et al. Implementing dementia care models in primary care settings: The Aging Brain Care Medical Home. Aging Ment Health. 2011;15(1):5-12. Exclusion code: 6. [pmid: 20945236].
30 Caplan GA, Williams AJ, Daly B, Abraham K. A randomized, controlled trial of comprehensive geriatric assessment and multidisciplinary intervention after discharge of elderly from the emergency department--the DEED II study. J Am Geriatr Soc. 2004;52(9):1417-1423. Exclusion code: 6. [pmid: 15341540].
31 Carpenter I, Gambassi G, Topinkova E, et al. Community care in Europe. The Aged in Home Care project (AdHOC). Aging Clin Exp Res. 2004;16(4):259-269. Exclusion code: 5. [pmid: 15575119].
32 Carr-Bains S, Nightingale AL, Ballard KD. Patients' experiences and satisfaction with out-of-hours GP home visiting provided by a GP cooperative. Fam Pract. 2011;28(1):88-92. Exclusion code: 2. [pmid: 20829278].
33 Cestari L, Currier E. Caring for the homebound elderly: a partnership between nurse practitioners and primary care physicians. HHCMP. 2001;13(5):356-360. PMID: None. Exclusion code: 8.
34 Chen C, Chen F, Mullan F. Teaching health centers: a new paradigm in graduate medical education. Acad Med. 2012;87(12):1752-1756. Exclusion code: 6. [pmid: 23095929].
35 Cho CY, Alessi CA, Cho M, et al. The association between chronic illness and functional change among participants in a comprehensive geriatric assessment program. J Am Geriatr Soc. 1998;46(6):677-682. Exclusion code: 6. [pmid: 9625181].
36 Contel JC, Badia JG. Home care in Spain: teamwork is the standard. Caring. 1998;17(12):42-44. Exclusion code: 9. [pmid: 10345608].
37 Corrieri S, Heider D, Riedel-Heller SG, Matschinger H, Konig HH. Cost-effectiveness of fall prevention programs based on home visits for seniors aged over 65 years: a systematic review. Int Psychogeriatr. 2011;23(5):711-723. Exclusion code: 14. [pmid: 21223626].
38 Cott CA, Falter LB, Gignac M, Badley E. Helping networks in community home care for the elderly: types of team. Can J Nurs Res. 2008;40(1):19-37. Exclusion code: 2. [pmid: 18459270].
39 Cravens DD, Mehr DR, Campbell JD, Armer J, Kruse RL, Rubenstein LZ. Home-based comprehensive assessment of rural elderly persons: the CARE project. J Rural Health. 2005;21(4):322-328. Exclusion code: 4. [pmid: 16294655].
40 Crome P, Malham A, Baker D, Smith AE, Bloor R. Domiciliary visits to the old and the mentally ill: how valuable?. J R Soc Med. 2000;93(4):187-190. Exclusion code: 2. [pmid: 10844884].
41 Czarnecki C, Crane S, Morley JE, Flaherty JH. A student-run Geriatric Home Health Care Program. Acad Med. 2001;76(2):199. Exclusion code: 6. [pmid: 11158847].
42 Davey A, Femia EE, Zarit SH, et al. Life on the edge: patterns of formal and informal help to older adults in the United States and Sweden. J Gerontol B Psychol Sci Soc Sci. 2005;60(5):S281-288. Exclusion code: 2. [pmid: 16131629].
43 Davies DE. Home-based care. Cmaj. 2012;184(2):214-215. Exclusion code: 9. [pmid: 22312027].
44 Del Sindaco D, Pulignano G, Minardi G, et al. Two-year outcome of a prospective, controlled study of a disease management programme for elderly patients with heart failure. J Cardiovasc Med (Hagerstown). 2007;8(5):324-329. Exclusion code: 6. [pmid: 17443097].
45 DeMiglio L, Williams A. Factors enabling shared care with primary healthcare providers in community settings: the experiences of interdisciplinary palliative care teams. Journal of Palliative Care. 2012;28(4):282-289. Exclusion code: 4. [pmid: 23413764].
46 Desai NR, Smith KL, Boal J. The positive financial contribution of home-based primary care programs: the case of the Mount Sinai Visiting Doctors. J Am Geriatr Soc. 2008;56(4):744-749. Exclusion code: 8. [pmid: 18331296].
47 Dettmar M. Annual diabetes reviews for housebound patients in primary care. Diabetes Prim Care. 2004;6(1):20-24. PMID: None. Exclusion code: 6.
48 Dinchris S. Health check-ups in resident homes. Nurs Older People. 2008;20(4):9-10. Exclusion code: 6. [pmid: 18549108].
49 Dogan H, Deger M. Nursing care of elderly people at home and ethical implications: an experience from Istanbul. Nurs Ethics. 2004;11(6):553-567. Exclusion code: 8. [pmid: 15597936].
50 Duckworth JM, Repede E, Elliott L. Nurse Practitioners Aiding Frail Elderly Through Home Visits. HHCMP. 2013;25(5):212-216. PMID: None. Exclusion code: 14.
51 Edes T. Comprehensive home care after hospitalization of elderly patients. JAMA. 1999;282(12):1129. Exclusion code: 3. [pmid: 10501107].
52 Edes T. Innovations in homecare: va home-based primary care. Generations. 2010;34(2):29-34. PMID: None. Exclusion code: 9.
53 Edwards DF, Baum CM, Meisel M, et al. Home-based multidisciplinary diagnosis and treatment of inner-city elders with dementia. Gerontologist. 1999;39(4):483-488. Exclusion code: 6. [pmid: 10495587].
54 Eklund K, Wilhelmson K. Outcomes of coordinated and integrated interventions targeting frail elderly people: a systematic review of randomised controlled trials. Health Soc Care Community. 2009;17(5):447-458. Exclusion code: 14. [pmid: 19245421].
55 Elkan R, Kendrick D, Dewey M, et al. Effectiveness of home based support for older people: systematic review and meta-analysis. BMJ. 2001;323(7315):719-725. Exclusion code: 6. [pmid: 11576978].
56 Elphick PR. House calls. Cmaj. 2004;171(12):1474-1475. Exclusion code: 9. [pmid: 15583193].
57 Espinel-Bermudez MC, Sanchez-Garcia S, Juarez-Cedillo T, Garcia-Gonzalez JJ, Viveros-Perez A, Garcia-Pena C. Impact of the program Home Care for the Chronically Ill for elderly: quality of life and hospital readmissions. Salud Publica Mex. 2011;53(1):17-25. Exclusion code: 6. [pmid: 21340136].
58 Fabris F, Molaschi M, Aimonino N, et al. Home care for demented subjects: new models of care and home-care allowance. Arch Gerontol Geriatr Suppl. 2004;(9):155-162. Exclusion code: 6. [pmid: 15207409].
59 Fagerstrom L, Wikblad A, Nilsson J. An integrative research review of preventive home visits among older people--is an individual health resource perspective a vision or a reality?. Scand J Caring Sci. 2009;23(3):558-568. Exclusion code: 6. [pmid: 19000086].
60 Farrell L. House call. BMJ. 2012;345:e6069. Exclusion code: 9. [pmid: 22993394].
61 Federman AD, Soriano T. More promise for home-based primary care. JAMA Intern Med. 2014;174(11):1804-1805. Exclusion code: 9. [pmid: 25222031].
62 Feltner C, Jones CD, Cene CW, et al. Transitional care interventions to prevent readmissions for persons with heart failure: a systematic review and meta-analysis. Ann Intern Med. 2014;160(11):774-784. Exclusion code: 9. [pmid: 24862840].
63 Ferrier C, Lysy P. Home assessment and care. Can Fam Physician. 2000;46:2053-2058. Exclusion code: 9. [pmid: 11072585].
64 Fifield J, Forrest DD, Martin-Peele M, et al. A randomized, controlled trial of implementing the patient-centered medical home model in solo and small practices. J Gen Intern Med. 2013;28(6):770-777. Exclusion code: 6. [pmid: 22956444].
65 Fjaertoft H, Indredavik B, Johnsen R, Lydersen S. Acute stroke unit care combined with early supported discharge. Long-term effects on quality of life. A randomized controlled trial. Clin Rehabil. 2004;18(5):580-586. Exclusion code: 6. [pmid: 15293492].
66 Fleischer S, Roling G, Beutner K, et al. Growing old at home - a randomized controlled trial to investigate the effectiveness and cost-effectiveness of preventive home visits to reduce nursing home admissions: study protocol [NCT00644826]. BMC Public Health. 2008;8:185. Exclusion code: 6. [pmid: 18507840].
67 Fleming M. The right care in the right place: the value of physician visits at home. Caring. 2011;30(6):20-22. Exclusion code: 9. [pmid: 21837907].
68 Fleming MO, Haney TT. Improving patient outcomes with better care transitions: the role for home health. Cleve Clin J Med. Electronic Suppl 1. 2013;80:eS2-6. Exclusion code: 9. [pmid: 23420797].
69 Frese T, Deutsch T, Keyser M, Sandholzer H. In-home preventive comprehensive geriatric assessment (CGA) reduces mortality--a randomized controlled trial. Arch Gerontol Geriatr. 2012;55(3):639-644. Exclusion code: 6. [pmid: 22790107].
70 Gammel JD. Medical House Call Program: extending frail elderly medical care into the home. J Oncol Manag. 2005;14(2):39-46. Exclusion code: 2. [pmid: 16018198].
71 Gene Badia J, Borras Santos A, Contel Segura JC, et al. Predictors of mortality among elderly dependent home care patients. BMC Health Serv Res. 2013;13:316. Exclusion code: 2. [pmid: 23947599].
72 Gene Badia J, Contel Segura JC. Proposals for the development of home care. Aten Primaria. 1999;23(4):183-184. 186. Exclusion code: 9. [pmid: 10333600].
73 Goldschmidt D, Groenvold M, Johnsen AT, Stromgren AS, Krasnik A, Schmidt L. Cooperating with a palliative home-care team: expectations and evaluations of GPs and district nurses. Palliat Med. 2005;19(3):241-250. Exclusion code: 8. [pmid: 15920939].
74 Goldschmidt D, Schmidt L, Krasnik A, Christensen U, Groenvold M. Expectations to and evaluation of a palliative home-care team as seen by patients and carers. Support Care Cancer. 2006;14(12):1232-1240. Exclusion code: 15. [pmid: 16703333].
75 Goodman C, Gordon AL, Martin F, et al. Effective health care for older people resident in care homes: the optimal study protocol for realist review. Syst Rev. 2014;3:49. Exclusion code: 2. [pmid: 24887325].
76 Gorodeski EZ, Chlad S, Vilensky S. Home-based care for heart failure: Cleveland Clinic's “Heart Care at Home” transitional care program. Cleve Clin J Med. Electronic Suppl 1. 2013;80:eS20-26. Exclusion code: 2. [pmid: 23420798].
77 Gruber E. On the road. House calls: home-based primary care. Nurse Practitioner World News. 2007;12(10):3. PMID: None. Exclusion code: 6.
78 Gutkin C. Visites a domicile -- redecouvrir un art perdu. Can Fam Physician. 2010;56(7):723-723. PMID: None. Exclusion code: 9.
79 Hansen LO, Young RS, Hinami K, Leung A, Williams MV. Interventions to reduce 30-day rehospitalization: a systematic review. Ann Intern Med. 2011;155(8):520-528. Exclusion code: 12. [pmid: 22007045].
80 Hayashi J, DeCherrie L, Ratner E, Boling PA. Workforce development in geriatric home care. Clin Geriatr Med. 2009;25(1):109-120. vii. Exclusion code: 2. [pmid: 19217496].
81 Hays R, Clarkson P, Tucker S, Challis D. Healthcare support services for care home residents. Nurs Older People. 2012;24(10):26-30. Exclusion code: 2. [pmid: 23301411].
82 Higgins N, Regan C. A systematic review of the effectiveness of interventions to help older people adhere to medication regimes. Age Ageing. 2004;33(3):224-229. Exclusion code: 6. [pmid: 15082425].
83 Jaarsma T, Brons M, Kraai I, Luttik ML, Stromberg A. Components of heart failure management in home care; a literature review. Eur J Cardiovasc Nurs. 2013;12(3):230-241. Exclusion code: 7. [pmid: 22707520].
84 Jacobs JM, Stessman J. The positive financial contribution of home-based primary care programs: generating revenue or reducing health expenditure?. J Am Geriatr Soc. 2008;56(12):2361-2362. Exclusion code: 9. [pmid: 19093945].
85 Javoric H, Topolovec-Nizetic V, Pavlekovic G. Home visits in Croatian family practice: a longitudinal study: 1995-2012. Coll Antropol. Suppl 2. 2014;38:55-59. Exclusion code: 7. [pmid: 25643528].
86 Jenei RA. A “waiver” program that keeps Ohio elders at home: PASSPORT in home health care. Home Healthc Nurse. 2010;28(3):140-146. Exclusion code: 9. [pmid: 20308808].
87 Jenkins P, Baker E, White B. Promoting good health in people aged over 75 in the community. Nurs Older People. 2009;21(2):34-39. quiz 40. Exclusion code: 9. [pmid: 19284031].
88 Johansson B, Holmberg L, Berglund G, et al. Reduced utilisation of specialist care among elderly cancer patients: a randomised study of a primary healthcare intervention. Eur J Cancer. 2001;37(17):2161-2168. Exclusion code: 6. [pmid: 11677102].
89 Johansson PE, Petersson GI, Nilsson GC. Personal digital assistant with a barcode reader--a medical decision support system for nurses in home care. Int J Med Inform. 2010;79(4):232-242. Exclusion code: 10. [pmid: 20138577].
90 Kamenski G, Fink W, Maier M, Pichler I, Zehetmayer S. Characteristics and trends in required home care by GPs in Austria: diseases and functional status of patients. BMC Fam Pract. 2006;7:55. Exclusion code: 9. [pmid: 17010213].
91 Kao H, Walter LC. Improvement of hospital care of elderly patients: thinking outside the (hospital) box: comment on “hospital at home for elderly patients with acute decompensation of chronic heart failure”. Arch Intern Med. 2009;169(17):1576-1577. Exclusion code: 9. [pmid: 19786676].
92 Kato G, Tamiya N, Kashiwagi M, Sato M, Takahashi H. Relationship between home care service use and changes in the care needs level of Japanese elderly. BMC Geriatr. 2009;9:58. Exclusion code: 6. [pmid: 20025749].
93 Kaufman J, Atamian W. Pushing the creative envelope. Collaborative practice models between physicians & agencies. Caring. 1998;17(12):16-18. Exclusion code: 9. [pmid: 10345602].
94 Kelly P. Physician assistant training in residentially based geriatric primary care at Central Michigan University. Perspect Physician Assist Educ. 2003;14(2):96-100. PMID: None. Exclusion code: 9.
95 Kersnik J. Observational study of home visits in Slovene general practice: patient characteristics, practice characteristics and health care utilization. Fam Pract. 2000;17(5):389-393. Exclusion code: 9. [pmid: 11021897].
96 King AI, Parsons M, Robinson E, Jorgensen D. Assessing the impact of a restorative home care service in New Zealand: a cluster randomised controlled trial. Health Soc Care Community. 2012;20(4):365-374. Exclusion code: 6. [pmid: 22106952].
97 Knight MM, Houseman EA. A collaborative model for the treatment of depression in homebound elders. Issues Ment Health Nurs. 2008;29(9):974-991. Exclusion code: 6. [pmid: 18770102].
98 Kretz SE. Outcomes and home health care. Healthc Inf Manage. 1996;10(2):9-17. Exclusion code: 16. [pmid: 10157654].
99 Kronhaus A. Home-based primary care: an innovative practice model for reducing costs and improving quality of care. N C Med J. 2014;75(5):332-333. Exclusion code: 2. [pmid: 25237873].
100 Landi F, Onder G, Russo A, et al. A new model of integrated home care for the elderly: impact on hospital use. J Clin Epidemiol. 2001;54(9):968-970. Exclusion code: 16. [pmid: 11520658].
101 Leff B, Kaffenbarger KP, Remsburg R. Prevalence, effectiveness, and predictors of planning the place of death among older persons followed in community-based long term care. J Am Geriatr Soc. 2000;48(8):943-948. Exclusion code: 8. [pmid: 10968299].
102 Leff B, Ritchie C. Quality-of-care standards missing for the vulnerable homebound. Mod Healthc. 2015;45(4):25. Exclusion code: 9. [pmid: 25671918].
103 Lewin G, De San Miguel K, Knuiman M, et al. A randomised controlled trial of the Home Independence Program, an Australian restorative home-care programme for older adults. Health Soc Care Community. 2013;21(1):69-78. Exclusion code: 6. [pmid: 23009672].
104 Liebel DV, Friedman B, Watson NM, Powers BA. Which components of a primary care affiliated home visiting nurse program are associated with disability maintenance/improvement?. Home Health Care Serv Q. 2012;31(2):155-180. Exclusion code: 16. [pmid: 22656915].
105 Low LF, Yap M, Brodaty H. A systematic review of different models of home and community care services for older persons. BMC Health Serv Res. 2011;11:93. Exclusion code: 6. [pmid: 21549010].
106 Lykkegaard J, Larsen PV, Paulsen MS, Sondergaard J. General practitioners' home visit tendency and readmission-free survival after COPD hospitalisation: a Danish nationwide cohort study. NPJ Prim Care Respir Med. 2014;24:14100. Exclusion code: 12. [pmid: 25429436].
107 Mai L, Eng J. Community-based elder care: a model for working with the marginally housed elderly. Care Manag J. 2007;8(2):96-99. Exclusion code: 8. [pmid: 17595928].
108 Manley J. Home health care in the continuum: a review. Continuum. 3. 1996;16(5):1-9. Exclusion code: 14. [pmid: 10162593].
109 Marcinowicz L, Chlabicz S, Gugnowski Z. Home visits by family physicians in Poland: patients' perspective. Eur J Gen Pract. 2007;13(4):237-238. Exclusion code: 9. [pmid: 18324506].
110 Marshall D, Howell D, Brazil K, Howard M, Taniguchi A. Enhancing family physician capacity to deliver quality palliative home care: an end-of-life, shared-care model. Can Fam Physician. 2008;54(12):1703-1703.e1707. Exclusion code: 8. [pmid: 19074714].
111 Marshall T. Home visiting by general practitioners in England and Wales. Home visits are a feature of primary care in many western European countries. BMJ. 1996;313(7064):1085. Exclusion code: 8. [pmid: 8898626].
112 Martin CM, Hogg W, Lemelin J, Nunn K, Molnar FJ, Viner G. Acute hospital services in the home. New role for modern primary health care?. Can Fam Physician. 2004;50:965-968. 972. 965. Exclusion code: 9. [pmid: 15317225].
113 Mattern R. Effectiveness of team-managed home-based primary care: a randomized multicenter trial. J Allied Health. 2001;30(2):132-133. PMID: None. Exclusion code: 9.
114 Matthews T, Weston N, Baxter H, Felce D, Kerr M. A general practice-based prevalence study of epilepsy among adults with intellectual disabilities and of its association with psychiatric disorder, behaviour disturbance and carer stress. J Intellect Disabil Res. 2008;52(Pt 2):163-173. Exclusion code: 9. [pmid: 18197955].
115 Maurer BT. House calls, homebodies: remembering that you came. JAAPA. 2010;23(6):61. Exclusion code: 9. [pmid: 20653265].
116 McCorkle R, Strumpf NE, Nuamah IF, et al. A specialized home care intervention improves survival among older post-surgical cancer patients. J Am Geriatr Soc. 2000;48(12):1707-1713. Exclusion code: 9. [pmid: 11129765].
117 McKinley RK, Cragg DK, Hastings AM, et al. Comparison of out of hours care provided by patients' own general practitioners and commercial deputising services: a randomised controlled trial. II: The outcome of care. BMJ. 1997;314(7075):190-193. Exclusion code: 6. [pmid: 9022435].
118 McKinney M. No place like home? Primary-care home option gets praise, questions. Mod Healthc. 2010;40(37):10. Exclusion code: 9. [pmid: 21322849].
119 McKinney M. Aging agencies help cut readmits. Mod Healthc. 2014;44(11):28. Exclusion code: 9. [pmid: 24830105].
120 McWilliam CL, Godfrey B, Stewart M, Sangster J, Mitchell J, Cohen I. Evolving the delivery of acute care services in the home. Home Health Care Serv Q. 2003;22(1):55-74. Exclusion code: 6. [pmid: 12749527].
121 Melis RJ, Adang E, Teerenstra S, et al. Cost-effectiveness of a multidisciplinary intervention model for community-dwelling frail older people. J Gerontol A Biol Sci Med Sci. 2008;63(3):275-282. Exclusion code: 16. [pmid: 18375876].
122 Meyer RP. Consider medical care at home. Geriatrics. 2009;64(6):9-11. Exclusion code: 9. [pmid: 19572761].
123 Millar DG, Carroll D, Grimshaw J, Watt B. Palliative care at home: an audit of cancer deaths in Grampian region. Br J Gen Pract. 1998;48(431):1299-1302. Exclusion code: 8. [pmid: 9747545].
124 Modin S, Tornkvist L, Furhoff AK, Hylander I. Family physicians' experiences when collaborating with district nurses in home care-based medical treatment. A grounded theory study. BMC Fam Pract. 2010;11:82. Exclusion code: 8. [pmid: 20979649].
125 Morales-Asencio JM, Gonzalo-Jimenez E, Martin-Santos FJ, et al. Effectiveness of a nurse-led case management home care model in Primary Health Care. A quasi-experimental, controlled, multi-centre study. BMC Health Serv Res. 2008;8:193. Exclusion code: 6. [pmid: 18811927].
126 Morin D, Aubin M, Vezina L, et al. From hospital to home after cardiac surgery: evaluation of a community nursing care management model. Prof Case Manag. 2009;14(4):167-175. quiz 176-167. Exclusion code: 6. [pmid: 19625933].
127 Morin D, Saint-Laurent L, Bresse MP, Dallaire C, Fillion L. The benefits of a palliative care network: a case study in Quebec, Canada. Int J Palliat Nurs. 2007;13(4):190-196. Exclusion code: 8. [pmid: 17551423].
128 Murashima S, Asahara K. The effectiveness of the around-the-clock in-home care system: did it prevent the institutionalization of frail elderly?. Public Health Nurs. 2003;20(1):13-24. Exclusion code: 6. [pmid: 12492821].
129 Murashima S, Zerwekh JV, Yamada M, Tagami Y. Around-the-clock nursing care for the elderly in Japan. Image J Nurs Sch. 1998;30(1):37-41. Exclusion code: 6. [pmid: 9549939].
130 Murray RR. The nurse practitioner and home care of the diabetic patient: the role of clinician and educator. HHCMP. 2001;13(5):367-374. PMID: None. Exclusion code: 14.
131 Nabagiez JP, Shariff MA, Khan MA, Molloy WJ, McGinn JT Jr. Physician assistant home visit program to reduce hospital readmissions. J Thorac Cardiovasc Surg. 2013;145(1):225-231. 233. discussion 232-223. Exclusion code: 6. [pmid: 23244257].
132 Nadarevic-Stefanec V, Malatestinic D, Mataija-Redzovic A, Nadarevic T. Patient satisfaction and quality in home health care of elderly islanders. Coll Antropol. Suppl 2. 2011;35:213-216. Exclusion code: 6. [pmid: 22220438].
133 Nadash P, Ahrens J. Bringing managed care home to the long-term care population. Cent Home Care Policy Res Policy Briefs. 2004;(18):1-6. Exclusion code: 2. [pmid: 15625748].
134 Naylor MD, Brooten D, Campbell R, et al. Comprehensive discharge planning and home follow-up of hospitalized elders: a randomized clinical trial. JAMA. 1999;281(7):613-620. Exclusion code: 6. [pmid: 10029122].
135 Naylor MD, Brooten DA, Campbell RL, Maislin G, McCauley KM, Schwartz JS. Transitional care of older adults hospitalized with heart failure: a randomized, controlled trial. [Erratum appears in J Am Geriatr Soc. 2004 Jul;52(7):1228]. J Am Geriatr Soc. 2004;52(5):675-684. Exclusion code: 16. [pmid: 15086645].
136 Naylor MD, Stephens C, Bowles KH, Bixby MB. Cognitively impaired older adults: from hospital to home. Am J Nurs. 2005;105(2):52-61. quiz 61-52. Exclusion code: 6. [pmid: 15674058].
137 Neff DF, Madigan E, Narsavage G. APN-directed transitional home care model: achieving positive outcomes for patients with COPD. Home Healthc Nurse. 2003;21(8):543-550. Exclusion code: 16. [pmid: 12917525].
138 Nguyen DL, DeJesus RS. Home health care may improve diabetic outcomes among non-English speaking patients in primary care practice: a pilot study. J Immigr Minor Health. 2011;13(5):967-969. Exclusion code: 5. [pmid: 21264514].
139 Oh KM, Warnes AM, Bath P. Effectiveness of a rapid response service for frail older people. Nurs Older People. 2009;21(5):25-31. quiz 32. Exclusion code: 6. [pmid: 19534170].
140 Ohwaki K, Hashimoto H, Sato M, Tamiya N, Yano E. Predictors of continuity in home care for the elderly under public long-term care insurance in Japan. Aging Clin Exp Res. 2009;21(4-5):323-328. Exclusion code: 6. [pmid: 19959921].
141 Okie S. Home delivery--bringing primary care to the housebound elderly. N Engl J Med. 2008;359(23):2409-2412. Exclusion code: 2. [pmid: 19052122].
142 Olsan TH, Shore B, Coleman PD. A clinical microsystem model to evaluate the quality of primary care for homebound older adults. J Am Med Dir Assoc. 2009;10(5):304-313. Exclusion code: 2. [pmid: 19497542].
143 Oreskovic S, Kuzman M, Budak A, Vrcic-Keglevic M, Ivankovic A. Doctor in the house: trends in GPs home visiting in Croatia 1990-1995 compared to current trends in USA and UK. Coll Antropol. 1997;21(2):595-608. Exclusion code: 7. [pmid: 9439077].
144 Orueta-Sanchez R, Gomez-Calcerrada RM, Gomez-Caro S, Sanchez-Oropesa A, Lopez-Gil MJ, Toledano-Sierra P. Impact on the primary carer of an intervention carried out on dependent elderly people. Aten Primaria. 2011;43(9):490-496. Exclusion code: 6. [pmid: 21536350].
145 Parker SG, Oliver P, Pennington M, et al. Rehabilitation of older patients: day hospital compared with rehabilitation at home. Clinical outcomes. Age Ageing. 2011;40(5):557-562. Exclusion code: 6. [pmid: 21685206].
146 Parsons M, Senior HE, Kerse N, et al. The Assessment of Services Promoting Independence and Recovery in Elders Trial (ASPIRE): a pre-planned meta-analysis of three independent randomised controlled trial evaluations of ageing in place initiatives in New Zealand. Age Ageing. 2012;41(6):722-728. Exclusion code: 16. [pmid: 22918089].
147 Partridge MR, Caress AL, Brown C, et al. Can lay people deliver asthma self-management education as effectively as primary care based practice nurses?. Thorax. 2008;63(9):778-783. Exclusion code: 5. [pmid: 18281394].
148 Path-Theta C. Optimizing chronic disease management mega-analysis: economic evaluation. Ont Health Technol Assess Ser. 2013;13(13):1-148. Exclusion code: 6. [pmid: 24228076].
149 Patriarche E, Danes MJ. Urinary incontinence. Nursing management. Care at home. Soins. 1998;(629):20. Exclusion code: 5. [pmid: 9934266].
150 Pereira EGA, Costa MAM. Health centers in Portugal and elderly care at home: a health care center study. [Portuguese]. Texto & Contexto Enfermagem. 2007;16(3):408-416. PMID: None. Exclusion code: 6.
151 Peters-Klimm F, Campbell S, Hermann K, et al. Case management for patients with chronic systolic heart failure in primary care: the HICMan exploratory randomised controlled trial. Trials. 2010;11:56. Exclusion code: 16. [pmid: 20478035].
152 Peterson LE. Response: re: trends in physician house calls to medicare beneficiaries. J Am Board Fam Med. 2014;27(1):160-161. Exclusion code: 2. [pmid: 24547598].
153 Peterson LE, Landers SH, Bazemore A. Trends in physician house calls to Medicare beneficiaries. J Am Board Fam Med. 2012;25(6):862-868. Exclusion code: 2. [pmid: 23136327].
154 Poulsen T, Siersma VD, Lund R, Christensen U, Vass M, Avlund K. Educational intervention and functional decline among older people: the modifying effects of social capital. Scand J Public Health. 2014;42(3):295-303. Exclusion code: 6. [pmid: 24504008].
155 Reckrey JM, Gettenberg G, Ross H, Kopke V, Soriano T, Ornstein K. The critical role of social workers in home-based primary care. Soc Work Health Care. 2014;53(4):330-343. Exclusion code: 4. [pmid: 24717182].
156 Rubenstein LZ, Stuck AE. Preventive home visits for older people: defining criteria for success. Age Ageing. 2001;30(2):107-109. Exclusion code: 3. [pmid: 11395336].
157 Running A, Walker T. Using nurse practitioners in home care. A report of two pilot projects. Home Healthc Nurse. 1999;17(11):731-738. Exclusion code: 2. [pmid: 10855132].
158 Russell D, Rosati RJ, Rosenfeld P, Marren JM. Continuity in home health care: is consistency in nursing personnel associated with better patient outcomes?. J Healthc Qual. 2011;33(6):33-39. Exclusion code: 6. [pmid: 22103703].
159 Rytter L, Jakobsen HN, Ronholt F, et al. Comprehensive discharge follow-up in patients' homes by GPs and district nurses of elderly patients. A randomized controlled trial. Scand J Prim Health Care. 2010;28(3):146-153. Exclusion code: 12. [pmid: 20429738].
160 Sahlen KG, Dahlgren L, Hellner BM, Stenlund H, Lindholm L. Preventive home visits postpone mortality--a controlled trial with time-limited results. BMC Public Health. 2006;6:220. Exclusion code: 6. [pmid: 16945128].
161 Sahlen KG, Lofgren C, Mari Hellner B, Lindholm L. Preventive home visits to older people are cost-effective. Scand J Public Health. 2008;36(3):265-271. Exclusion code: 6. [pmid: 18519295].
162 Scalvini S, Giordano A. Heart failure. Optimal postdischarge management of chronic HF. Nat Rev Cardiol. 2013;10(1):9-10. Exclusion code: 9. [pmid: 23165075].
163 Schaffer CL. Looking homeward. Managing care across the post-acute continuum. Health Syst Rev. 1997;30(4):30-32. 35. Exclusion code: 9. [pmid: 10169731].
164 Schumacher KL, Marren J. Home care nursing for older adults: state of the science. Nurs Clin North Am. 2004;39(3):443-471. vii. Exclusion code: 9. [pmid: 15331297].
165 Segura Noguera JM, Bastida Bastus N, Marti Guadano N, Riba Romeva M. The ATDOM programme in Raval Nord: descriptive analysis of 10 years of primary care. Aten Primaria. 2004;33(4):215-217. Exclusion code: 8. [pmid: 15023327].
166 Sharifi V, Tehranidoost M, Yunesian M, Amini H, Mohammadi M, Jalali Roudsari M. Effectiveness of a low-intensity home-based aftercare for patients with severe mental disorders: a 12-month randomized controlled study. Community Ment Health J. 2012;48(6):766-770. Exclusion code: 5. [pmid: 22772746].
167 Shepperd S, Harwood D, Gray A, Vessey M, Morgan P. Randomised controlled trial comparing hospital at home care with inpatient hospital care. II: cost minimisation analysis. BMJ. 1998;316(7147):1791-1796. Exclusion code: 6. [pmid: 9624069].
168 Shimetani N. The current status of home medical treatment and its development in the future. Rinsho Byori. 2006;54(4):344-348. Exclusion code: 8. [pmid: 16722453].
169 Shintani S, Shiigai T. Survival-determining factors in patients with neurologic impairments who received home health care in Japan. J Neurol Sci. 2004;225(1-2):117-123. Exclusion code: 8. [pmid: 15465094].
170 Shipman C, Addington-Hall J, Barclay S, et al. How and why do GPs use specialist palliative care services?. Palliat Med. 2002;16(3):241-246. Exclusion code: 9. [pmid: 12047001].
171 Sims-Gould J, Martin-Matthews A. We share the care: family caregivers' experiences of their older relative receiving home support services. Health Soc Care Community. 2010;18(4):415-423. Exclusion code: 9. [pmid: 20298503].
172 Solberg LI, Asche SE, Fontaine P, Flottemesch TJ, Anderson LH. Trends in quality during medical home transformation. Ann Fam Med. 2011;9(6):515-521. Exclusion code: 6. [pmid: 22084262].
173 Stausmire JM. Redesigning family medicine home visits to build trusting relationships---results of a 2-year study…. 2009 NACNS National Conference Abstracts. March 5-7, 2009. St. Louis, Missouri. Clin Nurs Spec. 2009;23(2):107-107. PMID: None. Exclusion code: 6.
174 Stephan A, Renom Guiteras A, Juchems S, Meyer G. The Balance of Care approach for the development of custom-fit health care services for people with dementia on the margins of care between home and nursing home: experiences with its application in Germany. Z Evid Fortbild Qual Gesundhwes. 2013;107(9-10):597-605. Exclusion code: 10. [pmid: 24315330].
175 Stessman J, Hammerman-Rozenberg R, Cohen A. Home hospitalization in the spectrum of community geriatric care. Disabil Rehabil. 1997;19(4):134-141. Exclusion code: 6. [pmid: 9158929].
176 Stewart EE, Nutting PA, Crabtree BF, Stange KC, Miller WL, Jaen CR. Implementing the patient-centered medical home: observation and description of the national demonstration project. [Erratum appears in Ann Fam Med. 2010 Jul-Aug;8(4):369]. Ann Fam Med. Suppl 1. 2010;8:S21-32. S92. Exclusion code: 12. [pmid: 20530392].
177 Stijnen MM, Duimel-Peeters IG, Jansen MW, Vrijhoef HJ. Early detection of health problems in potentially frail community-dwelling older people by general practices--project [G]OLD: design of a longitudinal, quasi-experimental study. BMC Geriatr. 2013;13:7. Exclusion code: 6. [pmid: 23331486].
178 Stijnen MMN, Jansen MWJ, Duimel-Peeters IGP, Vrijhoef HJM. Nurse-led home visitation programme to improve health-related quality of life and reduce disability among potentially frail community-dwelling older people in general practice: a theory-based process evaluation. BMC Fam Pract. 2014;15(1):2-26. Exclusion code: 7. [pmid: 24397621].
179 Stoltz P, Uden G, Willman A. Support for family carers who care for an elderly person at home - a systematic literature review. Scand J Caring Sci. 2004;18(2):111-119. Exclusion code: 14. [pmid: 15147473].
180 Storfjell JL, Brigell E, Christiansen K, et al. WOW specialty home care service for individuals with serious mental illness. HHCMP. 2008;21(1):23-32. PMID: None. Exclusion code: 2.
181 Strijbos JH, Postma DS, van Altena R, Gimeno F, Koeter GH. Feasibility and effects of a home-care rehabilitation program in patients with chronic obstructive pulmonary disease. J Cardiopulm Rehabil. 1996;16(6):386-393. Exclusion code: 6. [pmid: 8985797].
182 Stuart M, Weinrich M. Home- and community-based long-term care: lessons from Denmark. Gerontologist. 2001;41(4):474-480. Exclusion code: 2. [pmid: 11490045].
183 Sullivan CO, Omar RZ, Forrest CB, Majeed A. Adjusting for case mix and social class in examining variation in home visits between practices. Fam Pract. 2004;21(4):355-363. Exclusion code: 6. [pmid: 15249522].
184 Suter P, Hennessey B, Florez D, Newton Suter W. Review series: Examples of chronic care model: the home-based chronic care model: redesigning home health for high quality care delivery. Chron. 2011;8(1):43-52. Exclusion code: 2. [pmid: 21339374].
185 Takahashi PY, Haas LR, Quigg SM, et al. 30-day hospital readmission of older adults using care transitions after hospitalization: a pilot prospective cohort study. Clin Interv Aging. 2013;8:729-736. Exclusion code: 12. [pmid: 23818770].
186 Tandon SD, Parillo K, Mercer C, Keefer M, Duggan AK. Engagement in paraprofessional home visitation: families' reasons for enrollment and program response to identified reasons. Womens Health Issues. 2008;18(2):118-129. Exclusion code: 6. [pmid: 18182306].
187 Terol E, Hamby EF, Sacristan A, et al. An organizational model for a primary care program of home health care in Spain: a description of the program. Health Care Manag (Frederick). 2001;20(2):18-27. Exclusion code: 3. [pmid: 11809034].
188 Thume E, Facchini LA, Tomasi E, Vieira LA. Home health care for the elderly: associated factors and characteristics of access and health care. Rev Saude Publica. 2010;44(6):1102-1111. Exclusion code: 8. [pmid: 20835494].
189 Thume E, Facchini LA, Wyshak G, Campbell P. The utilization of home care by the elderly in Brazil's primary health care system. Am J Public Health. 2011;101(5):868-874. Exclusion code: 8. [pmid: 20724683].
190 van den Berg N, Meinke-Franze C, Fiss T, Hoffmann W. Changes in blood pressure in patients with hypertension in the context of delegated GP-home visits: a prospective implementation study. Blood Press Monit. 2013;18(2):63-71. Exclusion code: 6. [pmid: 23324878].
191 Van Houtven CH, Jeffreys AS, Coffman CJ. Home health care and patterns of subsequent VA and medicare health care utilization for veterans. Gerontologist. 2008;48(5):668-678. Exclusion code: 6. [pmid: 18981283].
192 Vass M, Avlund K, Kvist K, Hendriksen C, Andersen CK, Keiding N. Structured home visits to older people. Are they only of benefit for women? A randomised controlled trial. Scand J Prim Health Care. 2004;22(2):106-111. Exclusion code: 6. [pmid: 15255491].
193 Venner GH, Seelbinder JS. Team management of congestive heart failure across the continuum. J Cardiovasc Nurs. 1996;10(2):71-84. Exclusion code: 6. [pmid: 8656239].
194 Verhaegh KJ, MacNeil-Vroomen JL, Eslami S, Geerlings SE, de Rooij SE, Buurman BM. CHRONIC CARE. Transitional Care Interventions Prevent Hospital Readmissions For Adults With Chronic Illnesses. Health Aff (Millwood). 2014;33(9):1531-1539. Exclusion code: 6. [pmid: 25201657].
195 Vinker S, Nakar S, Weingarten MA. Home visits to the housebound patient in family practice: a multicenter study. Israeli General Practice Research Network. Isr Med Assoc J. 2000;2(3):203-206. Exclusion code: 8. [pmid: 10774267].
196 Voigt K, Tache S, Klement A, Fankhaenel T, Bojanowski S, Bergmann A. Gaining information about home visits in primary care: methodological issues from a feasibility study. BMC Fam Pract. 2014;15:87. Exclusion code: 7. [pmid: 24884460].
197 von Koch L, de Pedro-Cuesta J, Kostulas V, Almazan J, Widen Holmqvist L. Randomized controlled trial of rehabilitation at home after stroke: one-year follow-up of patient outcome, resource use and cost. Cerebrovasc Dis. 2001;12(2):131-138. Exclusion code: 6. [pmid: 11490107].
198 Wasserman S, de Villiers L, Bryer A. Community-based care of stroke patients in a rural African setting. S Afr Med J. 2009;99(8):579-583. Exclusion code: 6. [pmid: 19908616].
199 Whynes DK, Baines DL. Explaining variations in the frequency of night visits in general practice. Fam Pract. 1996;13(2):174-178. Exclusion code: 6. [pmid: 8732331].
200 Wyte-Lake T, Claver M, Griffin A, Dobalian A. The role of the home-based provider in disaster preparedness of a vulnerable population. Gerontology. 2014;60(4):336-345. Exclusion code: 4. [pmid: 24434836].
201 Yudin J. Sewing an all-inclusive quilt from home and community based services for frail elders: A community-academic house call program partnership. 2013. PMID: None. Exclusion code: 8.