# Included Studies

Please refer to this appendix as the reference list for Appendixes E and F.

1 Aabom B, Kragstrup J, Vondeling H, Bakketeig LS, Stovring H. Does persistent involvement by the GP improve palliative care at home for end-stage cancer patients?. Acad Nurs Palliat Med. 2006;20(5):507-512. [pmid: 16903404].
2 Anetzberger GJ, Stricklin ML, Gauntner D, Banozic R, Laurie R. VNA HouseCalls of greater Cleveland, Ohio: development and pilot evaluation of a program for high-risk older adults offering primary medical care in the home. Home Health Care Serv Q. 2006;25(3-4):155-166. [pmid: 17062516].
3 Beales JL, Edes T. Veteran's Affairs Home Based Primary Care. Clin Geriatr Med. 2009;25(1):149-154. viii. ix. [pmid: 19217499].
4 Beck RA, Arizmendi A, Purnell C, Fultz BA, Callahan CM. House calls for seniors: building and sustaining a model of care for homebound seniors. J Am Geriatr Soc. 2009;57(6):1103-1109. [pmid: 19457154].
5 Chang C, Jackson SS, Bullman TA, Cobbs EL. Impact of a home-based primary care program in an urban Veterans Affairs medical center. J Am Med Dir Assoc. 2009;10(2):133-137. [pmid: 19187882].
6 Cooper DF, Granadillo OR, Stacey CM. Home-based primary care: the care of the veteran at home. Home Healthc Nurse. 2007;25(5):315-322. [pmid: 17495561].
7 Counsell SR, Callahan CM, Clark DO, et al. Geriatric care management for low-income seniors: a randomized controlled trial. JAMA. 2007;298(22):2623-2633. [pmid: 18073358].
8 De Jonge E, Taler G. Is there a doctor in the house?. Caring. 2002;21(8):26-29. [pmid: 12739350].
9 Edes T, Kinosian B, Vuckovic NH, Nichols LO, Becker MM, Hossain M. Better access, quality, and cost for clinically complex veterans with home-based primary care. J Am Geriatr Soc. 2014;62(10):1954-1961. [pmid: 25333529].
10 Edwards ST, Prentice JC, Simon SR, Pizer SD. Home-based primary care and the risk of ambulatory care-sensitive condition hospitalization among older veterans with diabetes mellitus. JAMA Intern Med. 2014;174(11):1796-1803. [pmid: 25221986].
11 Hughes SL, Weaver FM, Giobbie-Hurder A, et al. Effectiveness of team-managed home-based primary care: a randomized multicenter trial. JAMA. 2000;284(22):2877-2885. [pmid: 11147984].
12 Neergaard MA, Vedsted P, Olesen F, Sokolowski I, Jensen AB, Sondergaard J. Associations between home death and GP involvement in palliative cancer care. Br J Gen Pract. 2009;59(566):671-677. [pmid: 19761666].
13 Neergaard MA, Vedsted P, Olesen F, Sokolowski I, Jensen AB, Sondergaard J. Associations between successful palliative trajectories, place of death and GP involvement. Scand J Prim Health Care. 2010;28(3):138-145. [pmid: 20698730].
14 Nichols LO, Martindale-Adams J, Burns R, Graney MJ, Zuber J. Translation of a dementia caregiver support program in a health care system--REACH VA. Arch Intern Med. 2011;171(4):353-359. [pmid: 21357811].
15 North L, Kehm L, Bent K, Hartman T. Can home-based primary care: cut costs?. Nurse Pract. 2008;33(7):39-44. [pmid: 18600171].
16 Ornstein K, Smith KL, Boal J. Understanding and improving the burden and unmet needs of informal caregivers of homebound patients enrolled in a home-based primary care program. J Appl Gerontol. 2009;28(4):482-503.
17 Ornstein K, Smith KL, Foer DH, Lopez-Cantor MT, Soriano T. To the hospital and back home again: a nurse practitioner-based transitional care program for hospitalized homebound people. J Am Geriatr Soc. 2011;59(3):544-551. [pmid: 21391944].
18 Ornstein K, Wajnberg A, Kaye-Kauderer H, et al. Reduction in symptoms for homebound patients receiving home-based primary and palliative care. J Palliat Med. 2013;16(9):1048-1054. [pmid: 23746230].
19 Rosenberg T. Acute hospital use, nursing home placement, and mortality in a frail community-dwelling cohort managed with Primary Integrated Interdisciplinary Elder Care at Home. J Am Geriatr Soc. 2012;60(7):1340-1346. [pmid: 22694020].
20 Wajnberg A, Wang KH, Aniff M, Kunins HV. Hospitalizations and skilled nursing facility admissions before and after the implementation of a home-based primary care program. J Am Geriatr Soc. 2010;58(6):1144-1147. [pmid: 20487075].