# Methods

We performed the systematic review in accordance with the Evidence-based Practice Center methods guides.1

This Appendix provides detail on the methods used to conduct this review. This supplements the briefer overview provided in the report and repeats what is also available in the protocol, which is posted for the public on the Agency for Healthcare Research and Quality (AHRQ) Web site: http://effectivehealthcare.ahrq.gov/ and registered in the PROSPERO database under registration number: CRD42015016714 at http://www.crd.york.ac.uk/PROSPERO/.

## Criteria for Inclusion/Exclusion of Studies in the Review

The criteria for inclusion and exclusion of studies were designed to identify studies that answer the Key Questions and are based on population, interventions, comparators, outcomes, timing, and setting (PICOTS).

Table A-1 Inclusion and exclusion criteria

| Include | Exclude
Population | Adults with chronic illnesses or disabilities | Children with special needs Adults being assessed for a single risk factor or condition Well elderly
Intervention(s) | HBPC as defined in Table 1 in the report | Care models that do not include the four required characteristics Examples of excluded care; preventive home visits, single visit home assessments, single purpose visits (fall risk assessments), care for a single condition, short-term home-based care such as Hospital at Home programs
Comparator(s) | Any other model of primary care | Services that are not primary care
Outcomes | Health Care Outcomes Patient and Caregiver Experience Utilization of Services | None
Timing | Longitudinal care, expected to continue until change in status | Short-term, time-limited home-based care such as Hospital at Home programs
Setting(s) | Patients' homes, broadly defined United States or other developed countries | Institutions such as nursing homes or prisons Countries with extremely different economies and/or health care systems
Study Design | - Randomized Controlled Trials; - High quality observational studies including: comparative cohort studies and time series; - Pre/post studies with or without a comparison group | - Descriptive studies; - Case series or reports; - Nonsystematic reviews
Publication Type | Peer reviewed journals Gray literature (if the study meets all other criteria) | Editorials or commentaries

We included studies that evaluated the effect of home-based primary care (HBPC) interventions, including randomized controlled trials and high-quality observational studies such as comparative cohort studies and time series. We included pre/post studies with or without a comparison group, though we highlighted the relative higher risk of bias in studies without a comparison group and we may have given more weight and attention to more rigorous study designs. We excluded case series and case reports as they are descriptive rather than assessments of effectiveness. We did not exclude studies based on any specific comparator or outcome; however, the comparators and approach to measuring the outcomes were considered as part of the assessment of the quality of an individual study and of the quality of the body of evidence.

Systematic reviews were used only to identify individual studies we may not have identified through our searches. This approach was based on our knowledge of the field and the results of Topic Refinement and preliminary searches, which suggested that there is not a large volume of literature, and that the scope and purpose of reviews conducted to date differ in key ways from those for this review.

We restricted inclusion to English-language articles and reviewed English-language abstracts of non-English-language articles in order to identify studies that would otherwise meet inclusion criteria and to assess the likelihood of language of publication bias.

## Literature Search and Triage

The primary searches included articles published between 1995 and May 2015. We confirmed through our literature scan and discussion with our Technical Expert Panel that the majority of programs began after 1997. We also checked reference lists of the included studies and systematic reviews to confirm that earlier studies were not missed. Library searches were designed and conducted by a medical librarian familiar with systematic reviews in consultation with the review team. Suggestions about search terms were requested and received from Technical Expert Panel members and these were evaluated and included when appropriate. Ovid MEDLINE, CINAHL, Clinical Trials.gov, and Cochrane Database of Systematic Reviews were searched to capture published literature. Gray literature will be identified by searching the NYAM gray literature database and the websites of organizations that may fund or produce research evaluating HBPC.

Requests for unpublished evaluation data on HBPC interventions were sent to professional organizations, organizations that fund or conduct research, and government agencies. Submissions were reviewed by the review team and assessed for relevance and quality. Reference lists of included articles were also reviewed for includable literature. If information regarding methods or results appeared to be omitted from the published results of a study, or if we were aware of unpublished data, we emailed the authors and request this information.

We established the criteria used to determine eligibility for inclusion and exclusion of abstracts in accordance with the Key Questions and the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.1 To ensure accuracy, all excluded abstracts were dual reviewed. The full text was retrieved for all citations deemed appropriate for inclusion by at least one of the reviewers. Each full-text article, including any articles suggested by peer reviewers or that may arise from the public posting process, was independently reviewed for eligibility by two team members. Any disagreements will be resolved by consensus.

The searches were updated while the draft report is posted for public comment and peer review to capture any new publications. Literature identified from the updated search was assessed by following the same process of dual review as all other studies considered for inclusion in the report. Any pertinent new literature was incorporated before the final submission of the report.

## Data Abstraction and Data Management

After studies were selected for inclusion, data was abstracted into categories including but not limited to: study design, year, setting, geographic location, sample size, eligibility criteria, patient characteristics, HBPC intervention characteristics, organizational characteristics, and results relevant to each Key Question as outlined in the PICOTS section. Information that was abstracted and relevant for assessing applicability includes the characteristics of the population, intervention, and care settings.

Abstracted study data was verified for accuracy and completeness by a second team member. A record of studies excluded at the full-text level with reasons for exclusion is included in Appendix C.

## Assessment of Risk of Bias

Predefined criteria were used to assess the quality of individual controlled trials, systematic reviews, and observational studies by using clearly defined templates and criteria as appropriate. Randomized trials and observational studies were evaluated according to criteria recommended in the AHRQ Methods Guide chapter, Assessing the Risk of Bias of Individual Studies When Comparing Medical Interventions.1 Individual studies were rated as “good,” “fair,” or “poor,” or as specified by the particular criteria. Studies rated “good” are considered to have low risk of bias and their results considered valid. Good-quality studies include clear descriptions of the population, setting, interventions, and comparison groups; a valid method for allocation of patients to treatment or identifying the treatment and control groups in observational studies; low dropout rates and clear reporting of dropouts; appropriate means of controlling for confounding; and appropriate measurement of outcomes.

Studies rated “fair” are susceptible to some bias, though not enough to invalidate the results. These studies may not meet all the criteria for a rating of good quality, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems. The fair-quality category is broad, and studies with this rating will vary in their strengths and weaknesses. The results of some fair-quality studies are likely to be valid, while for others the validity may be uncertain.

Studies rated “poor” have significant flaws that imply biases of various types that may invalidate the results. They have a serious or “fatal” flaw in design, analysis, or reporting; large amounts of missing information; discrepancies in reporting; or serious problems in the delivery of the intervention. The results of these studies areas likely to reflect flaws in the study design as the true difference between the compared interventions. We did not exclude studies rated as being poor in quality a priori, but poor-quality studies were considered to be less reliable than higher-quality studies when synthesizing the evidence, particularly if discrepancies between studies of differing quality were present.

Each study evaluated was dual-reviewed for quality by two team members. Any disagreements were resolved by consensus.

## Data Synthesis

We constructed evidence tables identifying the study characteristics, outcomes, and quality ratings for all included studies.

We reviewed and highlighted studies using a hierarchy-of-evidence approach. The best evidence available was the focus of our synthesis for each Key Question. If high-quality evidence was not available we described any lower-quality evidence we were able to identify, but underscored the issues that make it lower quality. We assessed and stated whether the inclusion of lower-quality studies would change any of our conclusions.

Meta-analyses are often considered to summarize data but before any statistical tests are done the interventions and outcomes are reviewed to determine if they are similar enough from a clinical perspective to combine. In this case the differences in how outcomes were defined and measured were extensive.. The Key Questions were designed to assess the comparative effectiveness and harms by patient demographics, comorbidities, and treatment features. Meta-regression was conducted to explore statistical heterogeneity using additional variables on methodological or other characteristics (e.g., quality, randomization or blinding, outcome definition and ascertainment) given a large enough number of studies.

## Grading the Strength of Evidence

The strength of evidence for each Key Question was initially assessed by one researcher for each outcome (see the PICOTS above), using the approach described in the AHRQ Methods Guide.1 To ensure consistency and validity of the evaluation, the grades were reviewed by the entire team of investigators for:

- Study limitations (low, medium, or high level of study limitations based on study design and the quality of the included studies)
- Consistency (consistent or inconsistent findings, or unknown)
- Directness (direct or indirect evidence)
- Precision (precise or imprecise estimates of effect)
- Reporting bias (suspected or undetected).

The strength of evidence was assigned an overall grade of high, moderate, low, or insufficient according to a four-level scale by evaluating and weighing the combined results of the above domains:

- High—We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions.
- Moderate —We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
- Low—We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Insufficient—We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

## Assessing Applicability

Applicability considers the extent to which results from a study or a body of evidence can be used to answer the questions of interest. Variability in the studies or studies with unique attributes may limit the ability to generalize the results to other populations, and settings. What may affect applicability can vary depending on the question of interest and currently the assessment of applicability is not standardized.

For this review we considered if applicability is affected by the characteristics of the patient populations (e.g., demographic characteristics, reason for receiving home-based care, primary condition or disability, presence of comorbidities) and the setting of the study (including geographic location and practice context).

## Peer Review and Public Commentary

We invited specialists including home-based primary care providers, health policy researchers, health care payers and providers, and patient caregiver/advocates to provide peer review the draft report. The AHRQ Task Order Officer and an Evidence-based Practice Center Associate Editor also suggested comments and provided editorial review. The draft report was posted on the AHRQ Web site for 3 weeks to acquire public comment. The disposition of comments report with responses from the authors to the peer review comments will be posted after publication of the final report on the AHRQ public Web site.

## Reference

1 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No.10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at: www.effectivehealthcare.ahrq.gov.