# Abbreviations and Acronyms

ACOVE: Assessing Care of Vulnerable Elders
ADL: Activities of daily living
AHRQ: Agency for Healthcare Research and Quality
CI: Confidence Interval
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CMS: Centers for Medicare & Medicaid Services
DO: Osteopathic physician
ED: Emergency department
EPC: Evidence-based Practice Center
GRACE: Geriatric Resources for Assessment and Care of Elders
HBPC: Home-based primary care
IAH: Independence at Home
MD: Allopathic physician
MEDLINE: Medical Literature Analysis and Retrieval System Online, or MEDLARS Online
NP: Nurse practitioner
OR: Odds ratio
PA: Physician assistant
PACE: Program of All-inclusive Care for the Elderly
PCMH: Patient-centered medical home
PCP: Primary care provider
PICOTS: Populations, Interventions, Comparators, Outcomes, Timing, and Setting
RCT: Randomized controlled trial
REACH: Resources for Enhancing Alzheimer's Caregiver Health
SNF: Skilled nursing facility
VA: U.S. Department of Veterans Affairs