# Abbreviations

AAC: adequate allocation concealment
ACS: acute coronary syndrome
ALT: alanine transaminase
Apo: apolipoprotein
ApoA-I: apolipoprotein A-I
ApoA-II: apolipoprotein A-II
AST: aspartate transaminase
ATP III: Adult Treatment Panel III (of the NCEP)
Ator: atovastatin
AUC: area under the curve
BAS: bile acid sequestrant
bid: twice daily
c: calculated
CABG: coronary artery bypass graft
C-amine: cholestyramine
CCT: controlled clinical trial
CEA: carotid endarterectomy
C-lam: colesevelam
CHD: coronary heart disease
CIMT: carotid intima-media thickness
Cmax: maximum plasma concentration
CPK: creatine phosphokinase
C-pol: colestipol
CT: conditional titration
CVD: cardiovascular disease
DHA: docosahexaenoic acid
dir: direct
DM: diabetes mellitus
eNOS: endothelial nitric oxide
EPA: eicosapentaenoic acid
ER: extended release (for niacin
Ez: ezetimibe
FF: fenofibrate
FH: familial hypercholesterolemia
FT: fixed titration
Fluv: fluvastatin
GF: gemfibrozil
GI: gastrointestinal
GRADE: Grading of Recommendations Assessment, Development and Evaluation
h: hour
HC: hypercholesterolemia
HDL-c: high density lipoprotein cholesterol
HDL _2 _: subfraction 2 of HDL-c
HDL _3 _: subfraction 3 of HDL-c
HF: heart failure
hsCRP: high sensitivity C-reactive protein
HeFH: heterozygous familial hypercholesterolemia
HMG CoA: hydroxymethylglutaryl coenzyme A
HoFH: homozygous familial hypercholesterolemia
HoFS: homozygous familial sitosterolemia
hsCRP: high sensitivity C-reactive protein
IMT: intima-media thickness
ITTA: intention to treat analysis
LDL-c: low density lipoprotein cholesterol
Lov: lovastatin
Lp(a): lipoprotein A
max: maximum
MD: mean difference
MetS: metabolic syndrome
mFF: micronized fenofibrate
MI: myocardial infarction
NIH: National Institutes of Health
NCEP: National Cholesterol Education Program
NIH: National Institutes of Health
non-HDL-c: non-HDL cholesterol
NPC1L1: Niemann-Pick C1-Like 1 sterol transporter
NR: not reported
NSAID: non-steroidal anti- inflammatory drug
od: once daily
OL: open label
Om3: omega-3-acid ethyl esters
OR: odds ratio
PCI: percutaneous coronary intervention
Pl: placebo
Prav: pravastatin
q: every
RLP: remnant-like particle
Ros: rosuvastatin
SB: single blind
Sim: simvastatin
t½: half-life (time for concentration to decrease to half the initial level)
T1DM: type 1 diabetes mellitus
T2DM: type 2 diabetes mellitus
TG: triglycerides
TIA: transient ischemic attack
tid: three times daily
VLDL: very low density lipoprotein
vs: versus
wk: week(s)
y: year(s