# Acknowledgments

The Evidence-based Practice Center would like to thank numerous individuals for their support of this review. The authors thank Lorri Puil, Tanya Horsley, Heather Clark, Renée Hessian, Robert Côté, Margaret Sampson, Nick Barrowman, Andra Morrison, Raymond Daniel, Chantelle Garritty, and Sophia Tsouros for their collective efforts.

EPC Program Director

David Moher, Ph.D.

Director, University of Ottawa Evidence-based Practice Center

AHRQ Contacts

- Beth A. Collins-Sharp, Ph.D., R.N.
- Director
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality Rockville, MD

- Shilpa H. Amin, M.D., M.B.Sc., FAAFP
- Task Order Officer
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD