# 3 Results

## Search Results

Searches identified 8451 bibliographic records from searches of MEDLINE (1966 to August Week 3 2008), EMBASE (1980 to 2008 Week 36) and CENTRAL (The Cochrane Library, Issue 3, 2008) using the Ovid interface, and limited to English language publications from 1980 or later. Scopus was searched to identify articles cited in eight reviewer nominated papers from earlier searches.21,46–52 An updated and expanded search to systematically capture observational studies (i.e. without an RCT filter and without date limits) was conducted in MEDLINE (1950 to August Week 3 2008). The search strategies for each database are presented in Appendix A. As well, 12 unique records were identified by hand searching reference lists of review papers, FDA data, and information provided by drug manufacturers to the Scientific Resource Center updated as of April 2008. One report was nominated by a reviewer.

Of the 8,464 unique records identified, 7,587 were excluded following initial screening, and 716 studies were excluded upon full-text screening, as detailed in Figure 2.

Figure 2

QUOROM flow chart

Overall, 131 reports of 101 trials were considered for quantitative or qualitative evidence syntheses to answer questions regarding comparisons of all statin plus non-statin hypolipidemic drug combinations of interest (Tables 4 and 5). Of these reports, 97 were randomized and four non-randomized controlled clinical trials.86–89 Thirty four additional companion reports of trials were included which occasionally contributed longer-term or additional data, but only the main trial report was used for trial identification (Table 6). No studies of observational design met inclusion criteria. Eight of ten randomized controlled crossover trials were excluded because reported data did not incorporate within-person differences for continuous outcomes and paired observations for dichotomous endpoints, while pre-crossover data were not reported.90–97 Excluded trials and reasons for exclusion are contained in Appendix B.

Table 4

Non-randomized studies included in evidence syntheses

Statin | Drug in combination with statin
Statin | Ezetimibe | Fibrates | Niacin | Bile Acid Sequestrants | Omega-3 Fatty Acids
Simvastatin | | | | Mol (1990)89
Lovastatin | Türk (2008)86 | | X | Ojala (1990)88 | X
Fluvastatin | | van Dam (2001)87

Table 5

Companion reports for primary studies included in evidence syntheses

Reports in bold italics provided analyzable crossover data

Main report | Companion reports | | | SIP/FDA reports
Geiss (2005) 119 | Geiss (2006) 200
Pearson (2005)117 | Pearson (2005)201 | Pearson (2006)202 | Denke (2006)203
Capuzzi (2003)155 | Capuzzi (2004)204
Masana (2005)167 | Gagne (2002)131 | Simons (2004)205
Davidson (2002)130 | Sager (2003)206 | | | FDA Extension Trial Report98
Nordoy (2001)165 | Nordoy (2003)207
Chan (2002)107 | Chan (2002)208 | Chan (2002)209 | Chan (2006)210
Nordoy (1998)177 | Nordoy (2000)211
Simons (1998)198 | Simons (1998)212
Wiklund (1993)134 | Vanhanen (1995)213 | Wiklund (1996)214
Insull (2004)182 | Insull (2005)215
Bays (2003)49 | Bays (2003)216 | Bays (2003)217 | Bays (2005)218
Taylor (2004)196 | Taylor (2007)219
Athyros (2005)160 | Athyros (2006)220
Ballantyne (2005)118 | Pearson (2007)221 | Abate (2008)222
Ballantyne (2003)126 | Ballantyne (2004)223
Bays (2004)154 | Ose (2007)147
Catapano (2006)193 | Abate (2008)222
Goldberg (2006)144 | Guyton (2008)153
Yokoyama (2007)141 | Tanaka (2008)224
Goldberg (2004)48 | | | | FDA Extension Trial Report99
Knapp (2001)172 | | | | FDA Companion Report100
Gagne (2002)132 | | | | FDA Companion Report101
Melani (2003)127 | | | | FDA Companion Report102
Kerzner (2003)129 | | | | FDA Companion Report103

Table 6

Evidence addressing key question 1 for statin plus ezetimibe versus statin monotherapy comparison

Outcome | Evidence availability | Key points
All-cause mortality | Yes | No trial comparing statin plus ezetimibe combination therapy with a higher dose of statin monotherapy reported estimable mortality in a population requiring intensive lipid lowering therapy. Seven trials of 6 to 12 weeks duration compared statin plus ezetimibe combination therapy with statin monotherapy without specifically employing higher statin monotherapy doses. The pooled result did not demonstrate a difference between these treatments for mortality in participants requiring intensive lipid lowering therapy.
Vascular death | Yes | No trials compared lower dose statin combination therapy with higher dose monotherapy in participants requiring intensive lipid lowering therapy. The pooled results of two trials reporting vascular mortality (for all participant risk strata and statin doses) was neutral.
Fatal myocardial infarction (MI) | Yes | Sparse data in short-term trials yielded indeterminate results.
Non-fatal MI | No
Any or unspecified MI | Yes | Result of a single short term trial was indeterminate.
Acute coronary syndrome (ACS) (encompassing unstable angina or acute MI) | No
Any cerebrovascular event | No
Hemorrhagic stroke | No
Ischemic stroke | No
Any or unspecified stroke | Yes | Result of a single trial with one event was indeterminate.
Transient ischemic attack (TIA) | No
Carotid endarterectomy (CEA) | No
Percutaneous coronary interventional procedure (PCI) | No
Coronary artery bypass graft procedure (CABG) | No
Any or unspecified revascularization procedure | No
Serious adverse events | Yes | No consistent difference was noted between statin plus ezetimibe combination and statin monotherapy in the occurrence of serious adverse events across all participants. A trend in favor of monotherapy was noted in high risk populations, using similar statin doses in combination with ezetimibe versus statin monotherapy.
Cancer | Yes | No consistent difference was noted between statin plus ezetimibe combination and statin monotherapy in the occurrence of cancer across two trials of 24 and 48 weeks duration.

Abbreviations: ACS = acute coronary syndrome, CABG = coronary artery bypass graft, CEA = carotid endarterectomy, MI = myocardial infarction, PCI = percutaneous coronary intervention, SAE = serious adverse event

Eligible FDA reports were either companions of already published randomized trials contributing previously unpublished data,98–103 or unpublished trials (Tables 4 and 6).104,105

There were no eligible studies exclusively in women or the elderly of 80 years of age or more. Five trials restricted recruitment to male gender.106–110

Authors were contacted to request additional data or data clarification associated with 50 randomized controlled trial reports.42,47–50,91,107,111–153 Additional data or clarification from authors were obtained for 15 reports within the stipulated timeframe.47,48,107,114,122,124,125,130,139,142,144,145,149,152,154

## Data Synthesis and Pooling

For randomized controlled trials with multiple unbalanced intervention arms for the two interventions of a statin plus other hypolipidaemic drug combination and statin monotherapy, within-trial within-intervention data pooling was undertaken if statistical heterogeneity was not substantial. This was undertaken to avoid a unit of analysis error arising from double counting an intervention arm. When heterogeneity was considered substantial, then one of the intervention arms was left out of data synthesis based on a priori methodology. A log of pooled trial intervention arms data, and arms that were selected for data syntheses when pooling could not be undertaken because of high or significant statistical heterogeneity, is presented in Appendix C.

## Statin Plus Ezetimibe Combination Therapy Versus Statin Monotherapy

### Overview of Included Studies

A total of 44 randomized controlled trials evaluated relative efficacy and/or harms of the combination of a statin plus ezetimibe 10 mg/day compared with statin monotherapy, in a total of 22489 randomized participants (Table 3). Additionally, one eligible controlled clinical trial provided data on mortality.86 Thirteen randomized trials had more than one associated journal or FDA report (Table 5).48,117–119,126,127,129,130,132,144,154,167,193 The longest available data were analyzed, and one of the companion reports was considered for trial referencing.

Table 3

Randomized controlled trials included in evidence syntheses

Trials are referenced according to the primary study

Reports in bold italics provided analyzable crossover data

Statin | Drug in combination with statin
Statin | Ezetimibe | Fibrates | Niacin | Bile Acid Sequestrants | Omega-3 Fatty Acids
Rosuvastatin | Kosoglou (2004)124 Ballantyne (2007)142 | Durrington (2004)125 | Capuzzi (2003)155 McKenney (2007)139 | Ballantyne (2004)122 | X
Atorvastatin | Cruz-Fernandez (2005)115 Stein (2004)156 Ballantyne (2003)126 Blagden (2007)140 Piorkowski (2007)157 Conrad (2008)158 Leiter (2008)159 | Athyros (2005)160 Athyros (2002)161 | Moore (2007)162 | Hunninghake (2001)133 Isaacsohn (1997)163 Heinonen (1996)164 | Nordoy (2001)165 Chan (2002)107
Simvastatin | Rodney (2006)111 Landray (2006)166 Farnier (2005)114 Brohet (2005)116 Masana (2005)167 Gaudiani (2005)121 Bays (2004)154 Feldman (2004)47 Goldberg (2004)48 Davidson (2002)130 Kosoglou (2002)106 Patel (2006)143 Berthold (2006)109 Chenot (2007)146 Shankar (2007)168 Kastelein (2008)42 Roeters van Lennep (2008)151 Gouni-Berthold (2008)110 Dobs (2003)169 | Grundy (2005)120 Muhlestein (2006)145 | Stein (1996)170 Ballantyne (2008)150 Ballantyne (2008)171 | Knapp (2001)172 Simons (1992)173 O'Brien (1990)174 Johansson (1995)137 | Hong (2004)175 Durrington (2001)176 Nordoy (1998)177 Davidson (1997)178 Liu (2003)179 Davidson (2007)180
Lovastatin | Kosoglou (2004)181 Kerzner (2003)129 | X | Insull, Jr. (2004)182 Hunninghake (2003)128 Gardner (1996)183 FDA Report (2008)104 FDA Report (2008)105 Vacek (1995)184 | Davidson (2001)185 Schrott (1995)186 | X
Pravastatin | Melani (2003)127 Dagli (2007)187 | Wiklund (1993)134 Napoli (1997)188 | O'Keefe, Jr. (1995)189 | Eriksson (1998)190 Ito (1997)108 Pravastatin Multicenter Study Group II (1993)191 Ismail (1990)135 Barbi (1992)136 | X
Fluvastatin | Stein (2008)148 | Derosa (2004)123 Smit (1995)192 | X | Sprecher (1994)52 | X
Mixed statins^*^ | Barrios (2005)112 Pearson (2005)117 Ballantyne (2005)118 Ballantyne (2004)46 Gagne (2002)132 Geiss (2005) 119 McKenney (2007)139 Goldberg (2006)144 Catapano (2006)193 Constance (2007)194 Reckless (2008)149 Roeters van Lennep (2008)151 | Athyros (2002)50 Shah (2007)195 | Taylor (2004)196 Bays (2003)49 McKenney (2007)139 Kuvin (2006)197 | Simons (1998)198 | Yokoyama (2007)141 Meyer (2007)199
Total trials | 44 | 11 | 16 | 17 | 10

* Either participants were on several different statins a priori and were randomized to add on non-statin treatment or placebo/no drug, or statins in combination and monotherapy within a trial were not identical in type.

Thirty-five trials were conducted in multiple centers and eight in a single center,106,109,110,124,146,157,181,187 while the number of participating center(s) was not reported in one trial.119

Partial or complete pharmaceutical industry sponsorship was reported for 36 of 44 trials,42,46–48,106,109–112,114–118,121,124,126,127,129,130,132,139,140,143,144,148,149,151,154,156,158,159,166–169,181,193,194 while funding was not reported or unclear for four trials.119,142,146,157

Total Jadad scores for trials ranged from 1 to 5, with a mean of 3 (SD 1.02). Twenty trials reported an appropriate method of randomization,42,48,111,112,114–117,127,130,140,144,148,151,154,158,159,169,193,194 while 10 reported an appropriate method of double blinding.48,111,114–116,148,154,158,159,169 Allocation concealment was reported to be adequate in 16 trials.42,48,111,117,118,127,130,144,148,154,158,159,166,169,193,194

Distribution of trials by geographical region was as follows:

- North America – 26 trials42,46–48,106,115,117,118,121,126,127,129,130,132,139,142,144,148,154,156,158,159,167,181,193,194
- Europe - 25 trials42,48,109,110,112,114–116,124,126,132,140,142,143,146,148,149,151,156–158,166,167,187,194
- Asia – four trials48,112,168,194
- Australia & New Zealand – three trials48,149,194
- Africa - four trials42,132,142,156
- Central and South America – five trials48,132,149,156,194
- Middle East – two trials114,194
- Not reported – three trials111,119,169

No trial reported power to assess clinical outcomes, or endpoint adjudication. Also, except for four trials,97,142,144,146 active clinical adverse event data collection was either not reported or unclear. Sparse evidence in subgroups was found that directly answered Key Question 3, as summarized in Table 8.

Table 8

Availability of evidence addressing key question 3 for statin plus ezetimibe versus statin monotherapy comparison

[table image]

Abbreviations: HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, TC = total cholesterol, TG = triglycerides

### Key Question 1: For patients who require intensive lipid-modifying therapy, what are the comparative long-term benefits, and rates of serious adverse events of coadministration of different lipid-modifying agents (i.e. a statin plus another lipid-modifying agent) compared with higher dose statin monotherapy?

#### Study Design and Population Characteristics

Clinical outcomes, serious adverse events or cancer were reported in 31 randomized trials, none of crossover design, randomizing 19107 participants, comparing statin plus ezetimibe combination therapy with statin monotherapy.42,47,48,110–112,114–117,121,126,127,129,130,140,142–144,149,151,154,156,158,159,166–169,193,194

No trial was exclusively in females, in participants of 80 years of age or over, or in participants of Asian or Hispanic descent. However, one trial was in those of African descent.111 A number of trials reported the ethnic composition of the trial population as follows:

- 23 trials reported a mean of 84 percent participants of European descent (range 54 to 99 percent)
- 18 trials reported a mean of 12 percent of African descent (range <1 to 100 percent)
- Eight trials reported a mean of 5 percent of Asian descent (range <1 to 11.4 percent)
- 10 trials reported a mean of 8 percent Hispanics (range 2 to 26 percent)

Trial duration ranged from six to 96 weeks, with an average of 15 weeks. On average 43 percent of participants were women (range 0 to 76 percent). One trial recruited only males.110 The average of mean ages of participants was 58 years (range of mean age, 32 to 66 years). Twelve trials recruited solely from outpatient settings,42,47,48,117,126,127,129,130,151,156,167,194 while 18 trials did not report recruitment setting. Mean Jadad score was 3.4 (range, 1 to 5) and 15 trials had adequate allocation concealment.42,48,111,117,127,130,144,149,154,158,159,166,169,193,194

Of these 31 trials, 15 were exclusively in participants requiring intensive lipid lowering treatment (i.e. participants with established vascular disease and/or diabetes mellitus and/or baseline LDL-c above 190 mg/dL).42,47,112,114–116,121,140,142–144,149,151,159,194 These 15 trials randomized 7349 participants.

Across trials, participants were of diverse clinical characteristics, including those with familial hypercholesterolemia and LDL-c above 190 mg/dL,42 diabetes mellitus,121,144,194 established vascular disease and/or CHD risk equivalent, 47,112,114–116,140,142,143 and impaired renal function,166 ethnicity of African descent,111 healthy males,110 and no prior statin exposure.140 Twenty-three trials incorporated a placebo/statin lead-in period in addition to diet, with or without a prior lipid lowering drug washout period.42,47,48,111,112,114–116,121,126,127,129,130,144,151,156,158,159,166,167,169,193,194 Most trials excluded participants with TG over 300–600 mg/dL, recent or unstable vascular disease, uncontrolled diabetes mellitus or hypertension, liver or muscle disease, high ALT, AST and CPK, or impaired renal function. Nine trials excluded participants with baseline LDL-c over 250 mg/dL,48,111,126,127,129,130,142,154,193 two trials excluded those with LDL-c over 160 mg/dL,159,167 and two excluded CHD or risk equivalent participants with LDL-c over 160 mg/dL.112,159 Seven trials provided ezetimibe plus statin as a combined single pill,112,144,149,151,154,193,194 14 employed a placebo in addition to statin monotherapy,42,111,114–117,140,143,156,158,159,166,167,169 and one trial used a placebo only in the extension phase of the study.126

Of non-randomized studies, only one controlled clinical trial directly compared statin combination therapy with the same statin monotherapy and reported only the outcome of mortality of all clinical outcomes and SAE of interest.86

#### Long-Term Efficacy, Serious Adverse Events, and Cancer

Comparing statin plus ezetimibe versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### All-cause mortality

All-cause mortality was reported for 24 trials in 14407 evaluable participants (Table 9). Four trials, in 1428 evaluable participants, provided treatment and followup during 24 weeks or longer.48,121,126,166 Of the four long-term trials, one provided estimable mortality odds of 7.51 (95% CI 0.38, 147.37) based on three deaths.166 This 24 weeks trial randomized 203 participants with chronic renal disease and no definitive indication for cholesterol lowering, to simvastatin 20 mg/day and ezetimibe or simvastatin 20 mg/day alone, with adequate allocation concealment. Across all 24 trials assessing all-cause mortality, eight trials on 4006 evaluable participants with a total of 15 deaths could be meta-analyzed (Appendix G, Figure G-1). These trials, of six to 24 weeks duration, did not exhibit lateral asymmetry in the funnel plot (Appendix G, Figure G-1). Sixteen of the 24 trials, including the shortest trial of two weeks duration in healthy males, did not register mortality. There was no significant difference in odds of all-cause mortality between statin plus ezetimibe therapy and statin monotherapy in this quantitative synthesis, which included trials with all statin types and doses, and trial participant 10 year CHD risk status (OR 0.95; 95% CI 0.37, 2.41). Meta-analysis restricted to thirteen trials in 11113 evaluable participants with adequate allocation concealment, five of which contributed evaluable data to meta-analysis,118,144,149,166,194 resulted in a pooled odds ratio for all-cause mortality of 1.07 (95% CI 0.38, 2.99) (Table 9), (Appendix G, Figure G-2).

Four trials, 24 weeks or less in follow up duration, investigated a lower dose of a specific statin in combination with ezetimibe 10 mg/day versus higher dose of the same statin monotherapy and reported the outcome of all-cause mortality. Statins were either simvastatin121,151,169 or atorvastatin.158 (Table 9). None of the trials registered any mortality.

Fourteen trials with 6275 evaluable participants reported all-cause mortality in participants requiring intensive lipid lowering therapy.114–116,118,121,140,142–144,149,151,159,193,194 Across these trials, participants were those with CHD and/or CHD risk equivalent including DM. The longest followup trial was of 24 weeks duration, which reported zero deaths.121 Meta-analysis of seven of the 14 trials with estimable odds resulted in a pooled odds ratio of 0.61 (95% CI 0.22, 1.71), based on a total of 15 deaths (Appendix G, Figure G-3). The remaining trials did not register any death. Six of 14 trials reported adequate allocation concealmet.118,144,149,159,193,194 A sensitivity analysis on the four trials with adequate allocation concealment and estimable data yielded an all-cause mortality odds ratio of 0.64 (95% CI 0.20, 2.04) (Appendix G, Figure G-3) (Table 9).118,144,149,194

Two 24 and 12 weeks trials comparing lower dose statin plus ezetimibe with a higher dose of the same statin monotherapy in those requiring intensive lipid lowering observed zero deaths (Table 9).121,151

One controlled clinical trial investigated high doses of fluvastatin, pravastatin or simvastatin in combination with ezetimibe 10mg/day versus highdoses of fluvastatin and pravastatin monotherapies in 84 renal transplant patients with hypercholesterolemia and mean baseline LDL-c of 129 mg/dL over a period of one year. No death was noted during the followup period (Table 10).

##### Vascular death

Four vascular deaths were reported in two trials with 1196 evaluable participants (Table 9).42,130 Both trials used simvastatin as combination and monotherapy, and had adequate allocation concealment. Followup duration was 96 weeks in the long-term trial that registered three vascular deaths in 720 participants requiring intensive lipid lowering—all with off treatment LDL-c above 210 mg/dL—yielding an odds ratio of 1.98 (95% CI 0.21, 19.14).42 For the two trials, the pooled odds ratio of vascular death was 2.70 (95% CI 0.38, 19.20) (Appendix G, Figure G-5).

One trial of 12-week duration employing adequately concealed treatment allocation, with 121 evaluable participants with mixed 10 year CHD risk, employing fixed dose treatment, permitted a comparison of a lower dose of a particular statin (simvastatin 20 mg/day) plus ezetimibe with a higher dose of the same statin as monotherapy (simvastatin 80 mg/day). This trial randomized an additional number of participants into other treatment arms that registered zero mortality data. Based on a single vascular death, the odds ratio was 8.05 (95% CI 0.16, 407.27).130

There was no evidence for the comparative analysis of a specific lower dose statin in combination with ezetimibe versus higher dose of the same statin monotherapy in participants requiring intensive lipid lowering therapy.

##### Fatal myocardial infarction

Based on a total of 1460 evaluable participants, three trials of less than 24 weeks duration reported four participants developing fatal myocardial infarction (Table 9) .142,149,156 One trial recruited participants with elevated lipid levels despite low dose atorvastatin,156 while two exclusively included those with CHD or risk equivalent.142,149 Pooled odds were 2.71 (95% CI 0.38, 19.30). Comparative analysis of a specific lower dose statin in combination with ezetimibe versus higher dose of the same statin monotherapy could not be permitted because either higher does of statins were employed142,156 or mixed statins were administered to one of the intervention arms.149

##### Any or unspecified myocardial infarction

One 12-week trial in patients admitted to the hospital for a recent coronary event compared simvastatin 40 mg/day in combination with ezetimibe 10 mg/day, with twice the dose of prior statin therapy. Eleven of 424 patients developed myocardial infarction, yielding an odds ratio 1.19 (95% CI 0.36, 3.97).149

##### Stroke

In a single trial on 200 evaluable participants with impaired renal function of 24 weeks duration, one participant developed stroke on simvastatin 20 mg/day plus ezetimibe as a combined pill.166 Compared with simvastatin 20 mg/day plus placebo, the odds ratio was 7.70 (95% CI 0.15, 388.20).

##### Serious adverse events

Participants experiencing serious adverse events were reported for 27 trials in 13463 evaluable participants (Table 9). Six trials, including 1893 evaluable participants of whom 191 had serious adverse events, were of 24–56 weeks in duration.48,121,126,130,166,167 However, odds ratios could not be pooled because of substantial statistical heterogeneity (I2 = 56%) (Appendix G, Figure G-6). All six trials failed to show a significant difference in SAE with no homogenous trend across the predefined covariates of heterogeneity. There was no obvious indication of funnel plot asymmetry for these trials. Gaudiani et al.‘s trial was exclusively in participants with diabetes mellitus,121 while Landray et al. focused on those with moderate to severe renal impairment.166 Others recruited more clinically diverse participants. Five of six trials compared identical statins in combination and monotherapy,48,126,130,166,167 and all but one126 investigated simvastatin.

Considering all statins and doses over any duration, pooling results of 24 out of 27 trials produced an odds ratio of 1.08 (95% CI 0.88, 1.33). Three short-term trials, none in high CHD risk participants, reported no serious adverse event (Table 9; Appendix G, Figure G-7).110,158,168 All but one trial, for which funding was not clearly reported, were funded by pharmaceutical industry.142 There was no significant lateral asymmetry on the funnel plot, with an Egger‘s regression intercept of 0.51, and two tailed p-value > 0.1. Although each trial showed no significant difference in SAE, of trials showing a trend in favor of monotherapy, 71% were in high risk participants with most employing similar doses of statins across combination and monotherapies.47,112,114,116,121,142,143,149,151,159

Four trials permitted analysis of a lower dose of a particular statin in combination with a higher dose of the same statin.47,121,158,169 Meta-analysis of the three simvastatin-ezetimibe combination and monotherapy (40 mg/day) trials in 927 participants (44 with serious adverse events) produced a nonsignificant odds ratio of 1.64 (95% CI 0.85, 3.19).47,121,169 Excluding one trial that used a conditional upward titration of simvastatin,47 the odds ratio remained nonsignificant (Table 9).

One trial employing atorvastatin 20 mg/day plus ezetimibe versus atorvastatin in moderately high risk participants and lasting six weeks did not register a single SAE.158

##### Cancer

Eleven of a total of 971 participants developed a malignancy while on similar doses of simvastatin in combination and as monotherapy, during two trials of 24 and 48 weeks duration.48,166 Pooling yielded a nonsignificant odds ratio of 3.99 (0.71, 22.28), (Table 9). Most trials did not report active surveillance for cancer detection nor how malignancies were defined or detected.

### Key Question 2: Do these regimens differ in reaching LDL-targets (or other surrogate markers), short-term side effects, tolerability, and/or adherence?

#### Study Design and Population Characteristics

Forty-four trials, one of crossover design,119 randomized 22,489 participants to compare statin plus ezetimibe combination with statin monotherapy, and recorded one or more surrogate efficacy or harms outcomes other than serious adverse events or cancer.42,46–48,106,109–112,114–119,121,124,126,127,129,130,132,139,140,142–144,146,148,149,151,154,156–159,166–169,181,187,193,194 There was no trial exclusively in females, while three trials exclusively recruited healthy male participants.106,109,151 One trial restricted recruitment to participants of African descent111 and three restricted recruitment exclusively to those of European descent.106,109,181

A number of trials reported the ethnic composition of the trial population:

- Thirty-one trials reported a mean of 87 percent participants of European descent (range 54 to 100 percent)
- Twenty trials reported a mean of 11 percent participants of African descent (range <1 to 100 percent)
- Nine reported a mean of 4 percent participants of Asian descent (range <1 to 11 percent)
- Twelve trials reported a mean of 7 percent Hispanic population (range 2 to 26 percent).

Mean trial duration was 14 weeks, ranging from 1–96 weeks. Across all trials, 42 percent of participants were women (range, 0 to 76 percent). The average of mean ages of participants was 56 years (range, 32 to 66 years). Sixteen trials recruited outpatients,42,46–48,117,126,127,129,130,139,151,156,167,181,187,194 while 25 did not report recruitment setting.106,109–112,114–116,118,119,121,132,140,142–144,148,154,157–159,166,168,169,193 The mean Jadad score was 3 (range, 1 to 5) and 17 trials had adequate allocation concealment.42,48,111,117,118,127,130,144,148,149,154,158,159,166,169,193,194

Twenty trials, randomizing 7635 participants, were exclusively in participants requiring intensive lipid lowering treatment (i.e. participants with established vascular disease and/or diabetes mellitus and/or baseline LDL-c above 190 mg/dL).42,47,112,114–116,119,121,132,140,142–144,146,149,151,157,159,187,194

Across trials, participants were of diverse clinical characteristics, including exclusively severe hypercholesterolemia (etiology unspecified),119 homozygous familial hypercholesterolemia132 familial hypercholesterolemia excluding homozygotes,42 diabetes mellitus,121,144,194 established vascular disease and/or CHD risk equivalent,47,112,114–116,119,140,142,143,146,149,151,157,159,187 impaired renal function,166 no prior statin exposure,140 and ethnicity of African descent.111 Five trials were exclusively in otherwise healthy hypercholestrolemic participants.106,109,110,124,181 Twenty-six trials incorporated a placebo/statin lead-in period in addition to diet, with or without a prior lipid lowering drug washout period.42,46–48,111,112,114–116,118,121,126,129,130,132,144,151,156,158,159,166,167,169,187,193,194 Most trials excluded participants with TG over 300–600 mg/dL, patients with recent or unstable vascular disease, uncontrolled diabetes mellitus and hypertension, liver and muscle disease or high ALT, AST, CPK and/or impaired renal function. Nine trials excluded participants with baseline LDL-c over 250 mg/dL,48,111,126,127,129,130,142,154,193 one trial excluded those with LDL-c over 160 mg/dL167 and two excluded high-risk patients with LDL-c over 160 mg/dL.112,159 Seven trials used an ezetimibe-statin combination pill,112,118,144,149,151,154,193,194 twenty used a placebo added to statin monotherapy,42,46,106,111,114–117,119,124,140,143,148,156,158,159,166,167,169,181 and one trial used placebo only in the extension phase of the study.126

Table 7

Evidence addressing key question 2 for statin plus ezetimibe versus statin monotherapy comparison

Outcomes | Evidence availability | Key points
Participants attaining ATP III LDL-c targets | Yes | Most trials comparing combinations with monotherapy favored combination therapy. Ezetimibe plus lower dose simvastatin combination therapy was superior to higher dose simvastatin monotherapy, significantly increasing the probability of reaching the LDL-c target in those in need of intensive lipid lowering, in a pooled estimate from 2 trials.
LDL-c | Yes | Two trials in populations requiring intensive lipid lowering (patients with diabetes mellitus) demonstrated a 10% to 20% greater percentage LDL-c reduction for combination therapy (simvastatin plus ezetimibe) compared with higher dose simvastatin monotherapy. Across all populations, lower dose statin in combination therapy caused greater LDL-c reductions than higher dose statin monotherapy.
HDL-c | Yes | A single trial in a group requiring intensive lipid lowering, comparing lower dose simvastatin plus ezetimibe combination therapy with higher dose simvastatin monotherapy, showed no significant difference. Combination therapy produced a significant 1% greater increase in HDL-c than monotherapy when generally similar statin doses (in combination and monotherapies) were compared in participants qualifying for intensive lipid lowering therapy.
TC:HDL-c ratio | Yes | A single trial in a group requiring intensive lipid lowering, comparing a lower dose simvastatin plus ezetimibe combination therapy with higher dose simvastatin monotherapy showed a significant difference favoring combination therapy. Combination therapy produced a greater reduction in TC:HDL ratio in participants requiring intensive lipid lowering therapy when similar or closer statin doses were used in combination and monotherapy.
Measure(s) of atherosclerosis | | A single trial over two years showed no significant difference between simvastatin plus ezetimibe compared with same dose of statin monotherapy in change in carotid-intima media thickness
Treatment adherence | Yes | A single trial comparing lower dose simvastatin in combination therapy with higher doses of simvastatin monotherapy found no significant difference. Similarly, comparing similar doses of statins in combination and monotherapies, no differences were measured between the statin plus ezetimibe combination therapy and statin monotherapy.
Participants experiencing at least one adverse event | Yes | No significant difference was noted across statin plus ezetimibe combinations compared with statin monotherapy, including a single trial comparing lower dose simvastatin in combination therapy with a higher dose of simvastatin monotherapy.
Withdrawal due to adverse events | Yes | No significant difference was noted across statin plus ezetimibe combinations compared with statin monotherapy, including comparisons of lower dose statin combination therapy with higher doses of the same statin monotherapy.
Participants developing AST and/or ALT > 3 the upper limit of normal, and/or hepatitis | Yes | No significant difference was noted across statin plus ezetimibe combinations compared with statin monotherapy, including comparisons of lower dose simvastatin combination therapy with higher dose simvastatin monotherapy.
Participants with myalgia | | No significant difference was noted across various doses of statin plus ezetimibe combinations compared with statin monotherapy
Participants with CPK above 10 times the upper limit of normal | | No significant difference was noted across statin plus ezetimibe combinations compared with statin monotherapy, including comparisons of lower dose simvastatin combination therapy with higher dose simvastatin monotherapy.
Participants with rhabdomyolysis | Yes | No case of rhabdomyolysis was noted in 8125 trial participants across 19 trials.

Abbreviations: ALT = alanine transferase, AST = aspartate transferase, ATP III = Third Adult Treatment Panel of the National Cholesterol Education Program, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, TC = total cholesterol, CPK = creatinine phosphokinase

#### LDL-c Targets and Other Surrogate Markers

Comparing statin plus ezetimibe versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants reaching ATP III LDL-c goals

During 23 trials on 15,944 evaluable participants, 11329 participants attained ATP III LDL-c targets (Table 11). The duration of trials ranged from six to 24 weeks with most trials of six- or 12-week duration. Except one, for which sponsorship was not clear, all were pharmaceutical industry sponsored.142 Substantial statistical heterogeneity (I2 = 93 percent) across trials precluded meta-analysis (Appendix G, Figure G-8). However, in 96 percent of trials, odds significantly favored the statin plus ezetimibe combination. All five trials with point estimates of odds greater than 10 in favor of combination therapy unclearly reported allocation concealment and employed similar doses of statin in both intervention arms.114–116,140,167 There was no significant lateral asymmetry on the funnel plot, with an Egger‘s regression intercept of −0.6, and two tailed p-value > 0.1. One trial comparing combination simvastatin plus ezetimibe with atorvastatin monotherapy in participants with type 2 diabetes mellitus, hemoglobin A1c below 8.5 percent and LDL-c above 100 mg/dL, demonstrated nonsignificant odds ratios when simvastatin 40 mg/day plus ezetimibe was compared with atorvastatin 40 mg/day monotherapy.144

Restricting the analysis to participants requiring intensive lipid lowering therapy, 18 trials evaluating 7731 participants also demonstrated significant statistical heterogeneity (I2 = 90 percent), precluding pooling of odds ratios (Table 11; Appendix G, Figure G-9). There was no significant lateral asymmetry on the funnel plot, with an Egger‘s regression intercept of −0.6, and two tailed p-value above 0.1. Sixteen of 18 trials yielded significant odds ratios favoring concomitant statin plus ezetimibe. Trials not demonstrating significant results had more potent statins (atorvastatin and rosuvastatin) in the monotherapy arms.144,193

Three trials, employing fixed dose and conditional statin titration, permitted comparison of a lower dose of a particular statin plus ezetimibe with a higher dose of the same drug as monotherapy. All were in CHD or risk equivalent participants (i.e. those requiring intensive lipid lowering therapy).47,121,151 Although all showed a significant advantage of combination therapy over a 12–24 week period, pooling was not possible because of substantial heterogeneity (Table 11; Appendix G, Figure G-10). When Feldman‘s trial employing conditional titration and demonstrating lower point estimate was excluded, heterogeneity was reduced and pooled odds were 7.21 (95% CI 4.20, 12.08) (Appendix G, Figure G-11).

##### LDL-c, percentage mean change from baseline

LDL-c data in the form of percentage mean change from baseline was reported for a total of 35 trials including 18,788 evaluable participants.42,46–48,109–112,114–118,121,124,126,127,129,130,132,139,140,142–144,154,156,158,159,166–169,193,194 Followup duration ranged from two to 96 weeks (mean 12 weeks), and 65 percent of trials were six or 12 weeks in length (Table 12).

Across trials, participant characteristics were diverse and included those who were exclusively of African descent,111 or of South Asian descent.168 Participants‘ health status varied from otherwise healthy,109,110,124 to severe hypercholesterolemia,42,119,132 established CHD or risk equivalent,47,112,114–116,119,121,140,142–144,159,194 or established renal disease.166

Meta-analysis was not possible given substantial statistical heterogeneity (I2 =97 percent). Percentage of LDL-c reduction did not show a consistent pattern across the pre-specified covariates of heterogeneity. However, 94 percent of trials demonstrated significant additional percentage reduction from baseline in favor of the statin plus ezetimibe combination ranging from 4 to 27 percent, compared with mostly similar doses of statin monotherapy (Appendix G, Figure G-12). Two trials did not reach statistical significance. One employed an identical low dose of simvastatin in combination as well as monotherapy in South Asians of mixed 10 year CHD risk,168 while the other compared a titrated dose of simvastatin 40 mg/day plus ezetimibe with the same dose of more potent rosuvastatin monotherapy in a mixed 10 year CHD risk population, 86 percent of whom were of European descent.139 There was no significant lateral asymmetry on the funnel plot, with an Egger‘s regression intercept of 1.6, and two tailed p-value greater than 0.1 (Appendix G, Figure G-12). Except for one trial for which funding was not clearly reported, all 34 were sponsored by the pharmaceutical industry.142

Of the 35 trials across different populations, six permitted comparison of lower dose combination simvastatin with a higher dose of it over an average follow up of 14 weeks (range 4 to 26). These six trials demonstrated heterogenous but significant additional percentage LDL-c reductions ranging from 3 to 20 percent in favor of combination therapy, with the exception of simvastatin 10 mg/day in combination therapy versus 80 mg/day monotherapy in the 12 week Davidson et al. trial (mean difference −0.53, 95% CI −5.39, 4.33).47,48,121,130,154,169 One trial that compared lower dose atorvastatin combination therapy with higher dose atorvastatin monotherapy showed a 20 percent significant additional reduction in favor of combination therapy (Table 12).158 In this subgroup of trials, no lateral asymmetry was evident in the funnel plot (Appendix G, Figure G-13). A further sensitivity analysis without Feldman et al‘s trial employing conditional titration of simvastatin did not eliminate substantial heterogeneity.

In participants who might require intensive lipid lowering therapy (i.e. participants with CHD and/or risk equivalent disease and/or those with baseline LDL-c ≥ 190 mg/dL), 18 trials with 6601 evaluable participants contributed efficacy data for a statin plus ezetimibe in comparison with statin monotherapy, for all statin doses (Table 12; Appendix G, Figure G-14). Statistical heterogeneity (I2 = 94 percent) precluded meta-analysis. All trials showed significant mean differences in LDL-c percentage change from baseline, in favor of combination therapy. Mean additional percentage reduction ranged from 4 to 27 percent. No significant lateral asymmetry was noted (intercept 0.85, two tailed p-value > 0.1). Heterogenity was further explored across trials in intensive lipid lowering populations, employing lower dose simvastatin 20 mg/day in combination therapy, with higher dose simvastatin 40mg/day monotherapy. Two trials, one each of fixed121 and conditional statin titrations,47 showed significant additional LDL-c reductions of 20 percent (95% CI −26.60, −14.40) and 10 percent (95% CI --13.19, -6.81) respectively, but heterogeneity remained substantial (I2 = 89 percent), precluding pooling of the two trials (Appendix G, Figure G-15).

##### HDL-c, percentage mean change from baseline

HDL-c, percentage mean change from baseline was reported for 32 trials on 18143 participants (Table 13).42,46–48,109,110,112,114–118,121,124,126,127,129,130,139,140,142,144,154,156,158,159,166–169,193,194 Participant characteristics were diverse across trials and mean trial duration was 13 weeks (range 2 to 96) with 63 percent trials of six or 12 week followup. No significant lateral asymmetry of the funnel plot was noted (intercept −0.28, two tailed p-value > 0.1) (Appendix G, Figure G-16). Substantial heterogeneity (I-squared, 54 percent) precluded meta-analysis. Thirty one percent of trials demonstrated significant increases in percentage HDL-c ranging from 2–6 percent, in favor of combination therapy. The heterogeneity could not be explained by any of the prespecified covariates, but when the analysis was restricted to trials of lower simvastatin dose in combination therapy versus higher monotherapy simvastatin doses, in trials with fixed doses or fixed titrations, the heterogeneity was eliminated and the pooled mean difference was 0.31 (95% CI −0.89, 1.52). A single trial permitted comparison of atorvastatin 20 mg/day in combination therapy versus 40 mg/day of atorvastatin monotherapy, with a mean difference of 2.40 (95% CI 1.97, 2.83) (Table 13, Appendix G, Figure G-17).

Meta-analysis of the 15 trials in 7020 participants requiring intensive lipid lowering therapy demonstrated a significant increase over baseline of percentage HDL-c with combination therapy compared with monotherapy using a statin of mostly similar doses, mean difference 1.53 (95 percent CI 0.81, 2.24).42,47,112,114–116,118,121,140,142,144,159,167,193,194 The pooled estimate was not associated with significant evidence of lateral asymmetry (Eggers intercept −1.06, two tailed p > 0.1) (Appendix G, Figure G-18).

One trial by Gaudiani et al compared fixed doses of simvastatin 20 mg/day in combination therapy with 40 mg/day monotherapy in 210 participants with type 2 diabetes mellitus on stable thiazolidinedione doses, with a baseline LDL-c over 100 mg/dL, some of whom had previously completed a simvastatin trial. This trial provided the only evidence comparing lower dose of a particular statin in combination with ezetimibe against higher dose monotherapy using the same drug.121 The nonsignificant percentage mean difference was −0.10 (−3.42, 3.22).

##### Total cholesterol:HDL-c ratio, percentage mean change from baseline

Total cholesterol:HDL-c ratio, percentage mean change from baseline was reported in 20 trials, including 11942 evaluable participants (Table 14).48,112,115,118,121,126,127,129,130,139,142,144,154,156,158,159,167,169,193,194 Followup duration ranged from four to 24 weeks with a mean of nine weeks. Trials included participants with CHD or risk equivalents,112,115,121,142,144,159,194 or a mixed risk group. Substantial statistical heterogeneity (I2 = 96 percent) precluded pooling of data. However, all but the six week trial of Goldberg et al. in participants with diabetes mellitus demonstrated statistically significant additional reductions favoring combination therapy ranging from 3 to 20 percent. Qualitatively, heterogeneity could not be explained in terms of pre-specified covariates. Lateral funnel plot asymmetry was significant (Eggers intercept −5.4, two tailed p = 0.04) (Appendix G, Figure G-19). Restricting the analysis to a comparison of lower statin dose in combination therapy versus higher statin dose monotherapy did not reduce heterogeneity across five simvastatin trials with no consistent direction of mean difference (Appendix G, Figure G-20). One atorvastatin trial comparing 20 mg/day of the drug in combination therapy with higher dose monotherapy, in moderately high risk participants, showed a significant difference favoring combination therapy (Table 14).

Ten randomized trials evaluating 4677 participants requiring intensive lipid lowering could not be pooled because of substantial statistical heterogeneity (I2 = 93 percent).112,115,118,121,142,144,159,167,193,194 Eighty percent of trials were six weeks in duration and all but one142 reported pharmaceutical industry funding. However, across all trials, statistically significant and consistent additional reductions in percentage change from baseline favoring combination therapy ranged from 3 to 20 percent (Table 14). This heterogeneity could not be explained based on the covariates of allocation concealment, trial duration, or lower compared with higher dose statin in combination and monotherapy respectively versus trials employing similar statin doses across interventions. The funnel plot of this set of trials did not demonstrate lateral asymmetry (Eggers intercept −8.2, two tailed p > 0.1) (Appendix G, Figure G-21).

One trial by Gaudiani et al compared fixed doses of simvastatin 20 mg/day plus ezetimibe with simvastatin 40mg/day, in 210 participants with type 2 diabetes mellitus on stable thiazolidinedione doses. These participants had baseline LDL-c above 100 mg/dL, and some had previously completed a simvastatin trial. The percentage mean difference favored combination therapy (−13.50 percent (95% CI −18.22, −8.78) (Table 14).121

##### Measure of atherosclerosis

A single placebo-controlled trial of two years duration in 642 evaluable participants with familial hypercholesterolemia and previously untreated LDL-c above 210 mg/dL compared change score from baseline in mean carotid intima-media thickness measured at the common carotid arteries, carotid bulbs, and internal carotid arteries.42 Compared with simvastatin 80 mg/day monotherapy, simvastatin 80 mg/day in combination with ezetimibe did not significantly change the arterial wall thickness. The combination therapy group experienced a mean increase of 11.1 μm, in contrast with 5.8 μm in the monotherapy group. The mean difference in change score in carotid intima-media thickness was 0.01 mm (95% CI −0.01, 0.02) (Table 15).

#### Harms and Treatment Adherence

Comparing statin plus ezetimibe versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants adherent to treatment

In twelve trials with a total of 5,625 evaluable participants, 5020 individuals were considered to have adhered to trial medications per investigators‘ criteria.42,46,48,115,127,130,139,142,143,149,156,166 Trial populations were clinically diverse and followup ranged from six to 96 weeks. Five trials did not add a placebo to statin monotherapy and therefore were not blinded,48,127,130,139,142 and one trial used a single pill for the combination treatment.149 The pooled odds ratio, for all types and doses of statins, was 0.97 (95% CI 0.74, 1.27), and the Egger‘s regression intercept was not significant for lateral asymmetry (0.39, two tailed p > 0.1) (Table 16; Appendix G, Figure G-22). Restricting analysis to the three trials of 24 weeks or more in duration, significant odds favoring combination therapy were found for the longest trial of two years duration.42,46,166 This trial was blinded and employed a placebo but compared an identical dose of simvastatin in both combination and monotherapy interventions.42

Treatment adherence for 268 evaluable participants with hypercholesterolemia was estimated from a single trial of 12 weeks duration employing lower dose statin plus ezetimibe, compared with higher dose statin monotherapy without a placebo. No significant differences were noted in treatment adherence with simvastatin 10 to 20 mg/day plus ezetimibe compared with simvastatin 40 to 80 mg/day [OR 0.53 (95% CI 0.21, 1.30)].130

##### Participants with at least one adverse event

Adverse events such as myalgia, hepatitis and elevated CPK, AST or ALT were reported for 21 trials.46–48,111,112,119,124,126,127,129,130,142,144,154,156,167,168 With 4912 out of 10023 participants experiencing events, the pooled odds ratio was 0.99 (95% CI 0.90, 1.08). Trial populations were clinically diverse and followup ranged from two to 52 weeks. There was no evidence of significant funnel plot asymmetry (Egger‘s intercept 0.30, two tailed p > 0.1) (Table 16; Appendix G, Figure G-23). Trials that were 24 weeks or more in duration likewise failed to detect any difference.46,48,126,167,187

One trial of 23 weeks duration allowed comparison of a lower dose of simvastatin (conditionally titrated) plus ezetimibe with a higher dose of simvastatin monotherapy, in 362 evaluable participants with CHD or risk equivalent disease.47 The odds of an individual experiencing any adverse event with combination therapy compared with monotherapy was 1.07 (0.66, 1.73).

##### Participants withdrawing due to adverse events

In 32 trials with a total of 13667 evaluable participants, 490 individuals withdrew due to adverse events.42,46–48,106,111,112,115,116,118,121,126,127,129,130,132,140,142–144,148,151,154,156,158,159,167–169,187,193,194 Trial populations were clinically diverse and followup ranged from two to 96 weeks with a mean duration of 15 weeks. Two trials of 12 and 24 weeks duration employing simvastatin and pravastatin as combination and monotherapy interventions reported zero withdrawals.168,187 The pooled odds ratio for all statin types and doses was 1.20 (95% CI 0.98, 1.46), but the Egger‘s regression intercept was significant for lateral funnel plot asymmetry (Egger‘s intercept 0.74, two tailed p value = 0.04) (Table 16; Appendix G, Figure G-24).

The odds ratio for withdrawal from treatment with a lower dose of a statin plus ezetimibe compared with higher dose of the same statin monotherapy was not significant for the atorvastatin and simvastatin trials (Table 16).

##### Participants with AST and/or ALT above three times the upper limit of normal, and/or hepatitis

In 27 trials reporting this composite outcome, of a total of 15730 evaluable participants, 125 developed laboratory and/or clinical evidence of hepatic dysfunction.46–48,106,111,115,116,118,119,121,126,127,129,130,132,140,142,144,148,149,154,156,159,167,169,193,194 Trial populations were clinically diverse and followup ranged from two to 52 weeks with an average of 14 weeks. Five trials did not provide estimable odds as no participant had any elements of this composite outcome.106,111,116,119,140 The pooled odds ratio, for all statins and doses, was 1.35 (95% CI 0.94, 1.94), while the Egger‘s regression intercept was 0.7 and not significant for lateral asymmetry (two tailed p >0.1) (Table 16; Appendix G, Figure G-25).

Odds of developing one of the composite outcomes with a lower dose of a particular statin plus ezetimibe compared with the same statin monotherapy could be estimated from five trials employing fixed dose or conditional titration in 1573 evaluable participants with hypercholesterolemia, nine of whom developed laboratory and/or clinical evidence of hepatic dysfunction.47,48,121,130,169 Simvastatin 10 mg/day to 20 mg/day in combination therapy compared with simvastatin 40 to 80 mg/day monotherapy yielded an odds ratio of 1.51 (95% CI 0.40, 5.75). Restricting the meta-analysis to the four trials employing fixed statin dosing yielded an odds ratio of 1.28 (95% CI 0.31, 5.30) (Table 16; Appendix G, Figure G-26 and G-27).48,121,130

##### Participants with myalgia

Among 15 trials, 125 (2.4 percent) of 5050 evaluable participants reported symptoms of myalgia.48,106,109,112,114,124,126,130,140,142,146,154,156,167,181 Trial populations were clinically diverse and followup ranged from one to 52 weeks. In two trials no participants developed myalgia.109,146 The pooled odds ratio, for all types and doses of statins, was 0.92 (95% CI 0.64, 1.33), while Egger‘s regression intercept of 0.25 was not significant for lateral asymmetry (two tailed p > 0.1) (Appendix G, Figure G-28).

No trial provided evaluable data comparing a lower dose of a particular statin plus ezetimibe with a higher dose of the same statin monotherapy.

##### Participants with CPK above 10 times the upper limit of normal

In 32 trials reporting CPK, 39 of a total of 20220 evaluable participants developed elevations in CPK more than 10 times upper limit of normal.42,46–48,106,111,112,114–119,121,126,127,129,130,139,140,142,144,148,149,154,156,159,166–169,193 Trial populations were clinically diverse and followup ranged from two to 96 weeks with an average of 14 weeks followup. Seventeen trials did not provide estimable odds as no participant developed CPK elevations to this extent.106,112,115–117,119,129,139,140,142,144,148,149,159,166,167,169 This included a 12 week trial in 133 evaluable participants with previously documented statin associated muscle-related side effects, treated with fluvastatin 80 mg/day in combination and monotherapy.148 Pooling of 15 trials yielded an odds ratio of 0.78 (95% CI 0.41, 1.49). The Egger‘s regression intercept of −0.07 was not significant for lateral asymmetry (two tailed p > 0.1) (Appendix G, Figure G-29).

Three trials, one with zero participants with elevated CPK,169 compared lower dose simvastatin plus ezetimibe with higher dose of the same statin monotherapy.47,121 Substantial heterogeneity precluded pooling, but in both trials elevated CPK was a rare event. Of the two trials with fixed rather than conditional dose assignment,121,169 one yielded an odds ratio of 7.91 (95% CI 0.16, 399.42).121

##### Participants with rhabdomyolysis

Nineteen trials reported zero incidence of rhabdomyolysis,46–48,111,112,114–116,129,132,142,146,148,154,156,159,167–169 including a 12 week trial in 133 evaluable participants with previously documented statin associated muscle related side effects, treated with Fluvastatin 80 mg/day in both combination and monotherapy. 148 Trial populations were clinically diverse and followup ranged from one to 48 weeks, with an average of 14 weeks. Five trials employed low dose statins in both combination and monotherapies.112,114–116,168 Rosuvastatin was investigated in only one trial.142 Two trials compared lower dose simvastatin plus ezetimibe with higher dose simvastatin monotherapy.47,169

### Key Question 3: Compared with higher dose statins, and to one another, do combination regimens differ in benefits and harms within subgroups of patients?

#### Study Design and Population Characteristics

The availability of trials addressing aspects of question 3 are depicted in Table 8.

#### Clinical Outcomes

Comparing statin plus ezetimibe versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### All-cause mortality

###### Participants with diabetes mellitus

Six deaths were reported among six trials, in 3016 evaluable participants with diabetes mellitus. Two trials reported no deaths, including a trial of 24 weeks duration comparing fixed lower dose simvastatin plus ezetimibe with higher dose monotherapy. 121,193 The pooled odds ratio for the four adequately concealed trials with estimable odds and followup ranging from six to 12 weeks was 0.40 (95% CI 0.08, 2.09) (Table 9; Appendix G, Figure G-30).118,144,149,194 Odds were not estimable for a specific lower dose statin plus ezetimibe compared with higher dose statin monotherapy in this subgroup.

###### Participants with established vascular disease

Ten deaths were reported among six trials in a total of 1963 evaluable participants, all with six to 12 week followup.114–116,140,143,149 Three trials reported zero deaths.114,116,140 Odds of all-cause mortality were nonsignificant 0.66 (95% CI 0.19, 2.31) for combination therapy versus monotherapy (Appendix G, Figure G-31). Only one trial reported adequate allocation concealment, for which odds were nonsignificant (Table 9).149 There was no evidence comparing a specific lower dose combination statin with higher dose monotherapy.

###### Participants of African descent

No mortality was noted over the six month trial by Rodney et al, using simvastatin 20 mg/day with placebo or ezetimibe in 247 individuals of African descent.111 There was no evidence comparing a lower dose statin in combination therapy with higher dose statin monotherapy using the same statin in this subgroup.

###### Female participants

One of two trials reporting mortality registered two deaths over a 12 week period in a subgroup of 128 females, odds 0.95 (95% CI 0.06, 15.75) (Table 9). There was no evidence providing estimable odds comparing a lower dose statin in combination therapy with higher dose monotherapy using the same statin in this subgroup.

##### Vascular death

###### Participants with baseline LDL-c ≥ 190 mg/dL

Three deaths from cardiovascular causes were reported for Kastelein et al‘s two year trial in 720 randomized participants with familial hypercholesterolemia, with baseline LDL-c above 210 mg/dL. Fixed dose simvastatin 80 mg/day was employed both in combination and monotherapy. The odds ratio of vascular death was 1.98 (95% CI 0. 21, 19.14) for the combination therapy, compared with monotherapy.42

#### LDL-c Targets and Other Surrogate Markers

Comparing statin plus ezetimibe versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants reaching ATP III LDL-c goals

###### Participants with diabetes mellitus

Nine trials in a total 4340 evaluable participants, with an average of seven weeks followup, reported that 2720 (63 percent) reached ATP III LDL-c goals.115,117,118,121,144,149,167,193,194 Most trials employed atorvastatin and simvastatin, in various doses. Significant statistical heterogeneity (I2 = 90 percent) precluded meta-analysis. Six trials demonstrated significant odds in favor of combination treatment ranging from two to 24 (Appendix G, Figure G-32). Trials not demonstrating significant differences employed either more potent statins in the monotherapy arms or several different statins.144,149,193 Larger effect sizes favoring combination therapy were associated with similar doses of statins in combination and monotherapy arms.

Gaudiani et al‘s trial in 70 evaluable participants compared a lower dose of a statin plus ezetimibe with higher dose monotherapy using the same statin. The odds ratio of 4.79 (95% CI 1.72, 13.35) favored the lower dose simvastatin plus ezetimibe combination.

###### Participants with established vascular disease

Six trials, with 1131 of 1922 evaluable participants achieving ATP III LDL-c goals, could not be pooled due to substantial statistical heterogeneity (I2 = 90 percent ) (Appendix G, Figure G-33).114–116,140,149,168 However, all six trials showed significant odds ratios in favor of combination treatment, with point estimates ranging from two to 19. Heterogenity could not be explained across the covariates of allocation concealment, trial duration, drug dose and funding. There was no evidence comparing any specific lower dose statin plus ezetimibe with higher dose monotherapy.

###### Participants of African descent

Pearson et al reported subgroup data on participants of African descent on stable statin treatment, who had not previously met ATP III target LDL-c.117 ATP III LDL-c goals were achieved by 109 of 208 evaluable participants of African descent with odds in favor of combination therapy [OR 3.47 (95% CI 1.90, 6.33)]. There was no evidence comparing lower dose statin plus ezetimibe therapy with higher dose statin monotherapy using the same statin.

###### Participants of Hispanic descent

Pearson et al reported subgroup data on participants of Hispanic descent on stable statin treatment, who had not previously met ATP III target LDL-c.117 ATP III LDL-c goals were achieved by 54 of 113 participants with odds favoring combination treatment, with and odds ratio of 7.82 (95% CI 3.14, 19.45). There was no evidence comparing a specific lower dose statin plus ezetimibe with higher dose statin monotherapy.

###### Female participants

Two trials in female participants with CHD, of six and 12 weeks followup, using various statin and ezetimibe comparisons, demonstrated 104 of 189 participants reaching ATP III goals. Farnier et al‘s trial compared low dose simvastatin plus ezetimibe combination with identical doses of simvastatin monotherapy, with a highly significant odds ratio of 17.64 (95% CI 6.86, 45.36). The trial by Reckless et al. detected no significant difference, comparing simvastatin 40 mg/day plus ezetimibe 10 mg/day with twice the dose of previous statin therapy in 76 participants (Table 11; Appendix G, Figure G-34).

##### LDL-c, percentage mean change from baseline

###### Participants with LDL-c above 190 mg/dL

Meta-analysis of two trials in 754 evaluable participants with homozygous and non-homozygous familial hypercholesterolemia yielded a difference in percentage mean change from baseline of -16.50 (95% CI −16.63, −16.37) in favor of combination treatment (Table 12; Appendix G, Figure G-35).42,132 Trials lasted 12 and 96 weeks respectively. There was no evidence comparing a specific lower dose statin combination with higher dose monotherapy of the same statin in this subgroup.

###### Participants with diabetes mellitus

Each of the seven trials with a total of 2627 evaluable participants providing evidence for this subgroup analysis showed significant differences in mean percentage change from baseline favoring combination treatment, with additional percentage LDL-c reduction ranging from 4 to 26 percent (Table 12; Appendix G, Figure G-36).118,121,144,154,167,193,194 Substantial heterogeneity (I2 = 93 percent) precluded meta-analysis. Covariates of allocation concealment, trial duration, and statin dose could not explain this heterogeneity. All trials were sponsored by pharmaceutical industry. Lateral asymmetry of the funnel was apparent.

Gaudiani et al‘s trial provided data evaluable for lower dose statin plus ezetimibe compared with higher doses of the same statin.121 It compared fixed doses of simvastatin 20 mg/day in combination therapy with simvastatin 40mg/day monotherapy, in 210 participants with type 2 diabetes mellitus and baseline LDL-c over 100 mg/dL, on stable thiazolidinedione doses, some of whom had previously completed a simvastatin trial. The percentage mean difference favoring combination therapy was −20.50 percent (95% CI −26.60 %, −14.40 %).

###### Participants with established vascular disease

Across six trials with relevant data, 1503 participants with CHD demonstrated significant differences in mean percentage change from baseline favoring combination treatment, with point estimates in the range of −26.90 to −9.40 (Table 12; Appendix G, Figure G-37).114–116,140,143,154 However, trial mean differences data could not be pooled because of heterogeneity (I2 = 93 percent ). Covariates of allocation concealment, trial duration, and statin dose could not explain this heterogeneity. All trials were sponsored by pharmaceutical industry. There was no evidence comparing a specific lower dose combination statin with higher dose monotherapy in this subgroup.

###### Participants of African descent

Meta-analysis of available data from two trials with 515 evaluable participants of African descent were considered for quantitative synthesis, but substantial statistical heterogeneity precluded pooling (I2 = 72 percent). Trials employed different statins in combination and monotherapy arms. However, both trials were associated with significant differences in mean percentage change from baseline favoring combination treatment; −17.20 percent (95% CI −21.13 %, −13.27 %) and −23.00 percent (95% CI −27.55 %, −18.45) over a 12 and six week period respectively (Table 12; Appendix G, Figure G-38).111,117 There was no evidence comparing a specific lower dose statin plus ezetimibe with higher dose monotherapy using the same statin in either subgroup. Farnier et al.‘s trial that evaluated one patient in each of the low dose simvastatin plus ezetimibe combination and simvastatin monotherapy treatment arms could not be considered for pooling because there was no measure of dispersion. Their trial reported 65 percent reduction from baseline in mean LDL-c with combination therapy and 0.67 percent increase with monotherapy over six weeks in the two patients with CHD.114

###### Participants of Hispanic descent

Pearson et al. reported subgroup data on participants of Hispanic descent on stable statin treatment who had not previous met ATP III target LDL-c.117 Over a six week followup, 147 Hispanic participants on ongoing statin therapy were randomized to add-on ezetimibe and placebo. The difference in mean percentage change from baseline was −21.10 (−27.16, −15.04) in favor of combination therapy. There was no evidence comparing a specific lower dose statin plus ezetimibe with higher dose statin monotherapy.

###### Female participants

Three trials in this subgroup compared simvastatin-ezetimibe combination therapy with simvastatin monotherapy over 4 to 12 weeks. The trial population was mixed130,169 or high risk,114 with the greatest significant additional reduction (up to 24 percent) in percentage LDL-c evident in females with prior CHD using combination therapy, compared with similar statin dose monotherapy. Mean percentage reductions varied from 13 to 24 percent and all significantly favored combination treatment. Substantial heterogeneity precluded meta-analysis. Heterogeneity persisted when the two trials permitting lower combination simvastatin comparison with higher dose simvastatin monotherapy in mixed risk population were analyzed separately (I2 = 63 percent) – trials were inconsistent in the direction of effect estimate (Table 12; Appendix G, Figures G-39 and G-40).130,169

##### HDL-c, percentage mean change from baseline

###### Participants with LDL-c above 190 mg/dL

Kastelein et al‘s two year trial in 720 randomized participants with familial hypercholesterolemia yielded a nonsignificant difference in percentage mean increase of 2.40 percent (95% CI −0.23 percent, 5.03 percent) (Table 13). Fixed dose simvastatin 80 mg was compared in combination and monotherapy.42

###### Participants with diabetes mellitus

Six trials in 2790 participants with diabetes could not be pooled, given substantial statistical heterogeneity (I2 = 55 percent ).118,121,144,167,193,194 Followup duration ranged from six to 24 weeks (mean 10 weeks). Heterogeneity could not be explained on the basis of statin dose, sponsorship, adequacy of allocation concealment or trial duration. Differences in mean ranged from −0.8 to 4 percent, with varying statistical significance. There was no obvious evidence of lateral asymmetry of the funnel plot ((Table 13; Appendix G, Figure G-41). Gaudiani et al‘s trial provided data comparing lower dose statin plus ezetimibe with higher doses of the same statin.121 It compared fixed doses of simvastatin 20 mg/day plus ezetimibe with simvastatin 40mg/day in 210 participants with type 2 diabetes mellitus on stable thiazolidinedione doses, and baseline LDL-c over 100 mg/dL, some of whom had previously completed a simvastatin trial. The percentage mean difference was −0.10 percent (95% CI −3.42, 3.22).

###### Participants with established vascular disease

A total of 924 evaluable participants with established CHD were analyzed in three randomized trials of less than 12 weeks duration, sponsored by the pharmaceutical industry and with unclear reporting of allocation concealment (Table 13).114,116,140 The pooled difference in means was nonsignificant, 0.04 (95% CI −1.63, 1.72). Similar statin doses were employed in both combination and monotherapy. There was no evidence comparing a specific lower dose statin in combination therapy with higher dose monotherapy in this subgroup.

###### Participants of African and Hispanic descent

Pearson et al. reported subgroup data on participants of African and Hispanic descent (Table 13). Participants on ongoing statin therapy were randomised to add-on ezetimibe or placebo. The mean differences in percentage change in HDL-c were 3.30 percent (95% CI 0.35, 6.25) in participants of African descent, and 0.30 percent (95% CI −3.64, 4.24) in those of Hispanic descent.117 There was no evidence comparing a specific lower dose combination statin with higher dose monotherapy in both subgroups.

##### Total cholesterol:HDL-c ratio, percentage mean change from baseline

###### Participants with diabetes mellitus

Six pharmaceutical industry sponsored trials of a mean of eight week followup (range 6 to 24 weeks) with 2790 evaluable participants yielded this ratio. Statistical heterogeneity between trials precluded meta-analysis (I2 = 90 percent). The individual mean differences in percentage change from baseline consistently and significantly favored combination therapy, with point estimates in the range of −17.30 to −3.4. The heterogeneity could not be explained based on duration, statin type and dosage, and adequacy of allocation concealment (Table 14). With this small number of trials, the funnel plot was suggestive of lateral asymmetry (Fig G-42). Gaudiani et al‘s trial provided data comparing lower dose statin plus ezetimibe with higher doses of the same statin.121 It compared fixed doses of simvastatin 20 mg/day plus ezetimibe with simvastatin 40mg/day in 210 participants with type 2 diabetes mellitus on stable thiazolidinedione doses, and baseline LDL-c over 100 mg/dL, some of whom had previously completed a simvastatin trial. The percentage mean difference was −13.50 percent (95% CI −18.22, −8.78).

###### Participants with established vascular disease

A single six week trial by Cruz-Fernandez et al randomized participants with established CHD on prior low dose atorvastatin therapy to ezetimibe or placebo (Table 14). A significant mean difference in percentage change from baseline of −19.90 percent (95% CI −22.31, −17.49) was noted in favor of combination treatment.115

##### Non-HDL-c, percentage mean change from baseline

###### Participants with diabetes mellitus

Six pharmaceutical industry sponsored trials of a mean of eight week followup (range 6 to 24 weeks) with 2790 evaluable participants yielded this outcome (Table 17). Statistical heterogeneity between trials precluded meta-analysis (I2 = 94 percent). The individual mean differences in percentage change from baseline consistently and significantly favored combination therapy, with additional non-HDL-c reductions of 4 to 24 percent. Compared with trials reporting adequate allocation concealment and employing relatively more potent statins for monotherapy, there was a trend of higher point estimates associated with trials with allocation poorly concealed or reported, or less potent statin monotherapy.118,121,167,194 With this small number of trials, the funnel plot was suggestive of lateral asymmetry (Appendix G, Figure G-43). There was no analyzable evidence comparing a specific lower dose statin in combination therapy with higher dose monotherapy.

#### Strength of Evidence

The strength of the available evidence was assessed as GRADE (Grading of Recommendations Assessment, Development and Evaluation) 225 for the key outcomes all-cause mortality, vascular death, serious adverse events and achieving ATP-III target LDL-c. Results generated using the GRADEpro software are presented in Tables H-1 to H-11 (Appendix H) can be summarized as follow:

1. Based on studies in participants requiring intensive lipid lowering therapy and comparing the combination of lower dose simvastatin plus ezetimibe to higher dose simvastatin, GRADE was “very low” for all cause mortality (2 trials) and participants reaching ATP III LDL-c goals (3 trials) (Appendix H, Table H-1).
2. Based on studies in participants requiring intensive lipid lowering therapy and comparing the combination of any dose statin plus ezetimibe to any dose statin, GRADE was “very low” for all cause mortality (14 trials), vascular death (1 trial) and participants reaching ATP III LDL-c goals (18 trials) (Appendix H, Table H-2).
3. Based on a single study in participants with baseline LDL-c above 190 mg/dL, GRADE was “very low” for vascular death for the combination of any dose statin plus ezetimibe compared to any dose statin (Appendix H, Table H-3).
4. Based on studies in participants with diabetes mellitus and comparing the combination of any dose statin plus ezetimibe to any dose statin,, GRADE was “very low” for all cause mortality (6 trials) and participants reaching ATP III LDL-c goals (9 trials) (Appendix H, Table H-4).
5. Based on six studies in participants with established vascular disease, GRADE was “very low” for all cause mortality and participants reaching ATP III LDL-c goals for the combination of any dose statin plus ezetimibe compared to any dose statin (Appendix H, Table H-5).
6. Based on a single study in participants of African descent, GRADE was “very low” for all cause mortality and participants reaching ATP III LDL-c goals for the combination of any dose statin plus ezetimibe compared to any dose statin (Appendix H, Table H-6).
7. Based on a single study in participants of Hispanic descent, GRADE was “very low” for participants reaching ATP III LDL-c goals for the combination of any dose statin plus ezetimibe compared to any dose statin (Appendix H, Table H-7).
8. Based on two studies in female participants, GRADE was “very low” for all cause mortality and participants reaching ATP III LDL-c goals for the combination of any dose statin plus ezetimibe compared to any dose statin (Appendix H, Table H-8).
9. Based on studies in participants regardless of baseline risk and comparing the combination of lower dose simvastatin plus ezetimibe to higher dose simvastatin, GRADE was “very low” for all cause mortality (3 trials), vascular death (1 trial), serious adverse events (3 trials) and participants reaching ATP III LDL-c goals (3 trials) (Appendix H, Table H-9).
10. Based on studies in participants followed up for more than 24 weeks and comparing the combination of any dose statin plus ezetimibe to any dose statin, GRADE was “very low” for all cause mortality (4 trials), vascular death (1 trial), and serious adverse events (6 trials) (Appendix H, Table H-10).
11. Based on studies in participants regardless of baseline risk and comparing the combination of any dose statin plus ezetimibe to any dose statin, GRADE was “very low” for all cause mortality (24 trials), vascular death (2 trials), serious adverse events (27 trials) and participants reaching ATP III LDL-c goals (23 trials) (Appendix H, Table H-11).

### Evidence Summary Tables: Statin Plus Ezetimibe Combination Therapy Versus Statin Monotherapy

Table 9

Quantitative syntheses of long-term outcomes (clinical, serious adverse events and cancer) for ezetimibe plus statin combination therapy compared with statin monotherapy

Ezetimibe long-term outcomes | Number of trials reporting outcome | Number in relevant treatment groups | Number of participants with events | Odds ratio | Lower CI | Upper CI
All-cause mortality
All trials, ≥ 24 weeks followup48,121,126,166 | 4 | 1428 | 3 (analyzable data from a single trial) | 7.51 | 0.38 | 147.37
All trials48,110,111,114–118,121,126,127,129,140,142–144,149,151,158,159,166,169,193,194 | 24 | 14407 | 18 | 0.95 | 0.37 | 2.41
All trials with adequate allocation concealment 48,111,117,118,127,144,149,158,159,166,169,193,194 | 13 | 11113 | 15 | 1.07 | 0.38 | 2.99
All trials investigating lower dose of statin in combination versus higher dose of the same as monotherapy Simvastatin121,151,169 | 3 | 539 | 0 | - | - | -
All trials investigating lower dose of statin in combination versus higher dose of the same as monotherapy Atorvastatin158 | 1 | 194 | 0 | - | - | -
Participants requiring intensive lipid lowering therapy114–116,118,121,140,142– 144,149,151,159,193,194 | 14 | 6275 | 15 | 0.61 | 0.22 | 1.71
Participants requiring intensive lipid lowering therapy - Adequate allocation concealment118,144,149,159,193,194 | 6 | 3687 | 12 | 0.64 | 0.20 | 2.04
Participants requiring intensive lipid lowering therapy - lower dose of statin in combination versus higher dose of the same as monotherapy Simvastatin121,151 | 2 | 439 | 0 | - | - | -
Participants with diabetes mellitus 118,121,144,149,193,194 | 6 | 3016 | 6 | 0.40 | 0.08 | 2.09
Participants with diabetes mellitus, trials with adequate allocation concealment118,144,149,193,194 | 5 | 2802 | 6 | 0.40 | 0.08 | 2.09
Participants with established vascular disease114–116,140,143,149 | 6 | 1963 | 10 | 0.66 | 0.19 | 2.31
Participants with established vascular disease, adequate allocation concealment149 | 1 | 424 | 8 | 0.99 | 0.24 | 4.01
Participants of African descent111 | 1 | 247 | 0
Female participants only | 2 | 128 | 2 | 0.95 | 0.06 | 15.75
Vascular death
All trials ≥ 24 weeks followup42 | 1 | 720 | 3 | 1.98 | 0.21 | 19.14
All trials42,130 | 2 | 1196 | 4 | 2.70 | 0.38 | 19.20
All trials with adequate allocation concealment42,130 | 2 | 1196 | 4 | 2.70 | 0.38 | 19.20
Simvastatin - lower dose (20mg/day) combination therapy versus higher dose (80 mg/day) monotherapy130 | 1 | 121 | 1 | 8.05 | 0.16 | 407.27
Participants requiring intensive lipid lowering therapy, with LDL-c ≥190 mg/dL42 | 1 | 720 | 3 | 1.98 | 0.21 | 19.14
Fatal Myocardial Infarction
All trials142,149,156 | 3 | 1460 | 4 | 2.71 | 0.38 | 19.30
Unspecified Myocardial Infarction
All trials149 | 1 | 424 | 11 | 1.19 | 0.36 | 3.97
Stroke (ischemic and/or hemorrhagic)
Stroke166 | 1 | 200 | 1 | 7.70 | 0.15 | 388.20
Serious Adverse Event(s)
All trials, ≥ 24 weeks followup48,121,126,130,166,167 | 6 | 1893 | 191 | - | - | -
All trials47,48,110–112,114–116,118,121,126,130,140,142–144,149,151,154,156,158,159,166–169,193 | 27 | 13463 | 489 | 1.08 | 0.88 | 1.33
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy Fixed dose only121,169 | 2 | 314 | 9 | 4.85 | 0.84 | 28.00
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy Fixed and/or conditional titration47,121,169 | 3 | 927 | 44 | 1.64 | 0.85 | 3.19
Atorvastatin
Lower dose statin in combination therapy versus higher dose monotherapy Fixed dose only158 | 1 | 194 | 0 | - | - | -
Cancer
All trials 48,166 | 2 | 971 | 11 | 3.99 | 0.71 | 22.28

Abbreviations: CI = 95% confidence interval, LDL-c = low density lipoprotein-c

Table 10

Summary of non-randomized evidence on ezetimibe plus statin combination therapy compared with statin monotherapy

Trial | Design Duration Downs and Black score | Patients (LDL-c mg/dL) | Monotherapy | Combination Therapy | Results | Limitations | Applicability | Conclusion
Türk (2008)86 Trial country NR Sponsor NR | CCT 1 year 19/28 | 84 renal transplant patients with hypercholestero lemia on high dose statins Mean baseline LDL-c = 129 mg/dL | High doses of fluvastatin or pravastatin n = 28 | High doses of fluvastatin or pravastatin or simvastatin plus ezetimibe 10 mg/day n = 56 | No death Other clinical outcomes of interest, SAE and cancer not reported | Excluded participants likely to experience liver or muscle related AEs Study was not powered for the outcome of mortality | Applicability restricted to renal transplant patients | Results are inconclusive

Abbreviations: AEs = adverse events, CCT = controlled clinical trial, LDL-c = low density lipoprotein-c, n = number in treatment arm, NR = not reported, SAE = serious adverse event

Table 11

Quantitative syntheses of incidence of participants attaining ATP III LDL-c targets, for ezetimibe plus statin combination therapy compared with statin monotherapy

| Number of trials reporting outcome | Number of participants in relevant treatment groups | Number of participants with events | Odds ratio | Lower CI | Upper CI
Relative probability of attaining ATPIII LDL-c goal
All trials47,112,114–118,121,126,127,129,130,140,142,144,148,149,151,156,167,168,193,194 | 23 | 15944 | 11329 | - | - | -
Participants requiring intensive lipid lowering therapy47,112,114–118,121,140,142,144,148,149,151,167,168,193,194 | 18 | 7731 | 5342 | - | - | -
Simvastatin
Lower dose statin in combination versus higher dose monotherapy Participants requiring intensive lipid lowering therapy47,121,151 | 3 | 652 | 386 | - | - | -
Simvastatin
Lower dose statin in combination versus higher dose monotherapy fixed dose and/or fixed titration only Participants requiring intensive lipid lowering therapy121,151 | 2 | 295 | 149 | 7.21 | 4.30 | 12.08
Participants with diabetesmellitus115,117,118,121,144,149,167,193,194 | 9 | 4340 | 2720 | - | - | -
Simvastatin
Lower dose statin in combination versus higher dose monotherapy Participants with diabetes mellitus 121 | 1 | 70 | 41 | 4.79 | 1.72 | 13.35
Participants with established vascular disease 114–116,140,149,168 | 6 | 1922 | 1131 | - | - | -
Participants of Hispanic descent 117 | 1 | 113 | 54 | 7.82 | 3.14 | 19.45
Participants of African descent 117 | 1 | 208 | 109 | 3.47 | 1.90 | 6.33
Female participants only | 2 | 189 | 104 | - | - | -

Abbreviations: ATP III = Third Adult Treatment Panel of the National Cholesterol Education Program, CI = 95% confidence interval, LDL-c = low density lipoprotein cholesterol

Table 12

Quantitative syntheses of LDL-c data, for ezetimibe plus statin combination therapy compared with statin monotherapy

| Number of trials reporting outcome | Number of participants in relevant treatment groups | Point Estimate | Lower CI | Upper CI
Difference in mean LDL-c percentage change from baseline (%)
All trials42,46–48,109–112,114–118,121,124,126,127,129,130,132,139,140,142–144,154,156,158,159,166–169,193,194 | 35 | 18788 | - | - | -
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy across all populations47,48,121,130,154,169 | 6 | 1942 | - | - | -
Atorvastatin
Lower dose statin in combination therapy versus higher dose monotherapy across all populations158 | 1 | 184 | −19.90 | −25.17 | −14.63
Participants requiring intensive lipid lowering therapy42,47,112,114–116,118,121,132,140,142–144,154,159,167,193,194 | 18 | 6601 | - | - | -
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy Participants requiring intensive lipid lowering therapy47,121 | 2 | 567 | - | - | -
Participants with baseline LDL-c>190 mg/dL42,132 | 2 | 754 | −16.50 | −16.63 | −16.37
Participants with diabetes mellitus118,121,144,154,167,193,194 | 7 | 2627 | - | - | -
Participants with diabetes mellitus Simvastatin Lower dose statin in combination versus higher dose monotherapy121 | 1 | 210 | −20.50 | −26.60 | −14.40
Participants with vascular disease114–116,140,143,154 | 6 | 1503 | - | - | -
All participants of African descent111,114,117 | 3 | 517 | - | - | -
All participants of Hispanic descent 117 | 1 | 147 | −21.10 | −27.16 | −15.04
Female participants only 114,130,169 | 3 | 456 | - | - | -
Female participants only
Simvastatin
Lower dose statin in combination versus higher dose monotherapy130,169 | 2 | 186 | - | - | -

Abbreviations: CI = 95% confidence interval, LDL-c = low density lipoprotein cholesterol

Table 13

Quantitative syntheses of HDL-c data, for ezetimibe plus statin combination therapy compared with statin monotherapy

| Number of trials reporting outcome | Number of participants in relevant treatment groups | Point estimate | Lower CI | Upper CI
Difference in mean HDL-c percentage change from baseline (%)
All trials42,46–48,109,110,112,114–118,121,124,126,127,129,130,139,140,142,144,154,156,158,159,166–169,193,194 | 32 | 18143 | - | - | -
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy – all participants48,121,130,154,169 | 5 | 1585 | 0.31 | −0.89 | 1.52
Atorvastatin
Lower dose statin in combination therapy versus higher dose monotherapy – moderately high risk158 | 1 | 184 | 2.40 | 1.97 | 2.83
Participants requiring intensive lipid lowering therapy42,47,112,114–116,118,121,140,142,144,159,167,193,194 | 15 | 7020 | 1.53 | 0.81 | 2.24
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy Participants requiring intensive lipid lowering therapy (diabetes mellitus)121 | 1 | 210 | −0.10 | −3.42 | 3.22
Participants with LDL-c>190 mg/dL42 | 1 | 720 | 2.40 | −0.23 | 5.03
Participants with diabetes mellitus118,121,144,167,193,194 | 6 | 2790 | - | - | -
Participants with vascular disease114,116,140 | 3 | 924 | 0.04 | −1.63 | 1.72
All participants of African origin117 | 1 | 267 | 3.30 | 0.35 | 6.25
All participants of Hispanic origin117 | 1 | 147 | 0.30 | −3.64 | 4.24

Abbreviations: CI = 95% confidence interval, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol

Table 14

Quantitative syntheses of TC:HDL-c ratio data, for ezetimibe plus statin combination therapy compared with statin monotherapy

| Number of trials | Number of participants in relevant intervention groups | Point estimate | Lower CI | Upper CI
Difference in mean TC:HDL-c ratio percentage change from baseline
All trials48,112,115,118,121,126,127,129,130,139,142,144,154,156,158,159,167,169,193,194 | 20 | 11942 | - | - | -
Lower dose simvastatin in combination therapy versus higher dose simvastatin monotherapy48,121,130,154,169 | 5 | 1585 | - | - | -
Lower dose atorvastatin in combination therapy versus higher dose atorvastatin monotherapy158 | 1 | 184 | −13.00 | −17.61 | −8.39
Participants in need of intensive lipid lowering therapy112,115,118,121,142,144,159,167,193,194 | 10 | 4677 | - | - | -
Simvastatin
Lower dose simvastatin in combination therapy versus higher dose simvastatin monotherapy Fixed dosing Participants with diabetes mellitus121 | 1 | 210 | −13.50 | −18.22 | −8.78
All participants with diabetes mellitus118,121,144,167,193,194 | 6 | 2790 | - | - | -
Participants with vascular disease115 | 1 | 444 | −19.90 | −22.31 | −17.49

Abbreviations: CI = 95% confidence interval, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, TC = total cholesterol

Table 15

Quantitative synthesis of carotid intima-media thickness data, for ezetimibe plus statin combination therapy compared with statin monotherapy

| Number of trials reporting outcome | Number of participants in relevant treatment groups | Point estimate | Lower CI | Upper CI
Mean difference in CIMT change score (mm)
All trials42 | 1 | 680 | 0.01 | −0.01 | 0.02

Abbreviations: CI = 95% confidence interval, CIMT = carotid intima-media thickness

Table 16

Quantitative syntheses of short-term harms and adherence to treatment, for ezetimibe plus statin combination therapy compared with statin monotherapy

Ezetimibe short-term harms and adherence | Number of trials reporting outcome | Number of participants in relevant treatment groups | Number of participants with events | Odds ratio | Lower CI | Upper CI
Adherence to treatment
All trials42,46,48,115,127,130,139,142,143,149,156,166 | 12 | 5625 | 5020 | 0.97 | 0.74 | 1.27
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy130 | 1 | 268 | 242 | 0.53 | 0.21 | 1.30
Participants experiencing at least one adverse event
All trials46–48,111,112,119,124,126,127,129,130,142,144,149,151,154,156,159,167,168,187 | 21 | 10023 | 4912 | 0.99 | 0.90 | 1.08
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy Conditionally titrated dose (Fixed or conditional titration)47 | 1 | 362 | 242 | 1.07 | 0.66 | 1.73
Withdrawal due to an adverse event
All trials42,46–48,106,111,112,115,116,118,121,126,127,129,130,132,140,142–144,148,151,154,156,158,159,167–169,187,193,194 | 32 | 13667 | 490 | 1.20 | 0.98 | 1.46
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy Fixed dose121,130,169 | 3 | 582 | 27 | 1.43 | 0.49 | 4.23
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy Fixed dose or conditionally titrated47,121,130,169 | 4 | 1195 | 59 | 1.13 | 0.57 | 2.25
Atorvastatin
Lower dose statin in combination therapy versus higher dose monotherapy Fixed dose121,130,169 | 1 | 194 | 2 | 0.20 | 0.01 | 4.22
AST and/or ALT ≥ 3 times the upper limit of normal, and/or hepatitis
All trials46–48,106,111,115,116,118,119,121,126,127,129,130,132,140,142,144,148,149,154,156,159,167,169,193,194 | 27 | 15730 | 125 | 1.35 | 0.94 | 1.94
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy – fixed dose or fixed titration48,121,130,169 | 4 | 971 | 8 | 1.28 | 0.31 | 5.30
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy – conditional or fixed titrations or fixed dose47,48,121,130,169 | 5 | 1573 | 9 | 1.51 | 0.40 | 5.75
Myalgia
All trials48,106,109,112,114,124,126,130,140,142,146,154,156,167,181 | 15 | 5050 | 125 | 0.92 | 0.64 | 1.33
CPK ≥ 10 times the ULN
All trials42,46–48,106,111,112,114–119,121,126,127,129,130,139,140,142,144,148,149,154,156,159,166–169,193 | 32 | 20220 | 39 | 0.78 | 0.41 | 1.47
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy fixed dose or fixed titration 47,169 | 2 | 313 | 1 | 7.91 | 0.16 | 399.42
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy47,121,169 | 3 | 915 | 3 | - | - | -
Rhabdomyolysis (investigator defined)
All trials46–48,111,112,114–116,129,132,142,146,148,154,156,159,167–169 | 19 | 8125 | 0 | - | - | -
Atorvastatin
Lower dose statin in combination therapy versus higher dose monotherapy 159 | 1 | 564 | 0 | - | - | -
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy 47,169 | 2 | 713 | 0 | - | - | -

Abbreviations: ALT = alanine transaminase, AST = aspartate transaminase, CI = 95% confidence interval, CPK = creatinine phosphokinase, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, TC = total cholesterol, ULN = upper limit of normal

Table 17

Quantitative syntheses of non-HDL-c, for ezetimibe plus statin combination therapy compared with statin monotherapy

| Number of trials | Number of participants in relevant intervention groups | Point estimate | Lower CI | Upper CI
Difference in mean non-HDL-c percentage change from baseline
All trials118,121,144,167,193,194 | 6 | 2790 | - | - | -

Abbreviations: CI = 95% confidence interval, HDL-c = high density lipoprotein cholesterol

## Statin Plus Fibrate Combination Therapy Versus Statin Monotherapy

### Overview of Included Studies

A total of 11 randomized controlled trials evaluated the relative efficacy and/or harms of the combination of statins plus fibrates (fenofibrate 200mg/day, gemfibrozil 1200 mg/day) versus statin monotherapy in a total of 1991 participants (Table 3; Appendix F, Tables F-9 to F-16).50,120,123,125,134,145,160,161,188,192,195 One included non-randomized study addressed this particular comparison (Table 4).87 Two randomized trials had one or more companion reports of the same trial (Table 5).160,220 Data from the report with the longest available duration were used for analysis, and one of the companion reports was considered for trial referencing.

Three trials were conducted in multiple centers,120,125,134 and five in a single center,50,145,188,192,195 while this information was not reported for three trials.123,160,161 Three of 11 trials were partially or completely sponsored by the pharmaceutical industry,125,134,145 one study explicitly reported being conducted independently of industry funding,160 and reports of seven trials did not disclose funding sources.50,120,123,161,188,192,195 Mean Jadad score was 2 (range 1 to 3). Two trials were reported to be appropriately randomized,50,160 while five used an appropriate method for double blinding.120,123,134,145,192 Allocation concealment was adequate in two trials 50,160 and five trials used intention-to-treat analysis.123,145,160,161,192

Trials were distributed by geographical region as follows:

- North America - two trials 120,145
- Europe - eight trials 50,123,125,134,160,161,188,192
- Asia - one trial 195

Reporting of participants’ ethnicity was provided in three trials as follows:

- European descent (97 to 100 percent)120,123,125
- Hispanic descent (6.5 percent)120
- African descent (2.8 percent)120

Power analyses regarding the primary outcome measures were reported for no trials, and except for three trials,134,188,192 active clinical adverse event data collection was either not reported or unclear.

### Key Question 1: For patients who require intensive lipid-modifying therapy, what are the comparative long-term benefits, and rates of serious adverse events of coadministration of different lipid-modifying agents (i.e. a statin plus another lipid-modifying agent) compared with higher dose statin monotherapy?

#### Study Design and Population Characteristics

One or more clinical outcomes or serious adverse events were reported for five trials, none using crossover design, that randomized 990 participants to compare a fibrate-statin combination with statin monotherapy (Table 21; Appendix F, Table F-9).120,123,125,134,188

Three trials provided information on participants‘ descent, with a mean of 90 to 100 percent of participants of European descent,120,123,125 2.8 percent of African descent,120 and 6.5 percent of Hispanic descent.120

No trial was conducted exclusively in a single gender. On average, 45 percent of participants were female (range 33 to 50 percent). The average of mean ages of participants was 55 years (range of mean ages, 49 to 60 years). Three trials recruited outpatients,125,134,188 while two trials did not report recruitment setting. The mean Jadad score was 2 (range 1 to 3) and one trial had adequate allocation concealment.120 Two trials were exclusively in participants requiring intensive lipid lowering treatment (i.e. participants with established vascular disease and/or diabetes mellitus and/or baseline LDL-c above 190 mg/dL).125,134 These two trials randomized 297 participants.

Participants in these five trials were of heterogeneous characteristics, including those with familial combined hypercholesterolemia,120,188 diabetes mellitus,125 established vascular disease and/or CHD risk equivalent and/or diabetes mellitus,123 and prior statin exposure.120,123 Most trials excluded participants with triglycerides above 300 to 600 mg/dL, patients with recent or unstable vascular disease, uncontrolled diabetes mellitus and hypertension, liver or muscle disease or high ALT, AST or CPK, or impaired renal function. No trial reported employing a fibrate-statin combination as a combined pill.

Table 18

Evidence addressing key question 1 for statin plus fibrate versus statin monotherapy comparison

Outcomes | Extractable data availability | Key points of evidence synthesis
All-cause mortality | Yes | Three trials used the same statins in combination therapy and monotherapy, one with higher dose monotherapy. A significant difference was not observed among participants with mixed risk factors. These trials reported 3 deaths in 339 evaluable participants.
Vascular death | No
Fatal myocardial infarction (MI) | Yes | Two trials used the same statin and same dose in combination therapy and monotherapy. A significant difference was not observed among participants with mixed risk factors. These trials reported 1 fatal MI in 194 evaluable participants.
Non-fatal MI | Yes | One trial compared combination therapy with same statin and same dose monotherapy in participants with diabetes mellitus. No events were reported. This trial reported no events in 48 evaluable participants.
Any or unspecified MI | Yes | One trial compared combination therapy with the same statin and same dose monotherapy in participants with diabetes mellitus. No events were reported. This trial reported no events in 48 evaluable participants.
Acute coronary syndrome (ACS) (encompassing unstable angina or acute MI) | Yes | One trial compared combination therapy with same statin and same dose monotherapy in participants with diabetes mellitus. No events were reported. This trial reported no events in 48 evaluable participants.
Any cerebrovascular event | No
Hemorrhagic stroke | No
Ischemic stroke | No
Any or unspecified stroke | No
Transient ischemic attack (TIA) | No
Carotid endarterectomy (CEA) | No
Percutaneous coronary interventional procedure (PCI) | No
Coronary artery bypass graft procedure (CABG) | No
Any or unspecified revascularization procedure | No
Serious adverse events (SAEs) | Yes | Two trials compared combination therapy with the same statin and same dose monotherapy. SAEs were reported in a single trial and a significant difference was not observed. These trials reported 17 SAEs in 652 evaluable participants.
Cancer | No

Abbreviations: ACS = acute coronary syndrome, CABG = coronary artery bypass graft, CEA = carotid endarterectomy, MI = myocardial infarction, PCI = percutaneous coronary intervention, SAE = serious adverse event

#### Longer Term Efficacy, Serious Adverse Events, and Cancer

Comparing statin plus fibrate versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### All-cause mortality

All-cause mortality was reported for three trials in 339 evaluable participants.125,134,188 One long-term trial, in 27 participants, compared pravastatin 40 mg/day plus gemfibrozil 1200 mg/day with pravastatin 40 mg/day in participants with familial type II-b hyperlipoproteinemia or familial combined hyperlipidemia188 No deaths were reported throughout followup of 48 to 92 weeks. Across these three trials of 12 to 92 weeks duration, two trials on 297 evaluable participants had a total of three deaths (Table 21; Appendix F, Table F-9). These could be meta-analyzed without asymmetry evident (Appendix G, Figure G-44).125,134 A nonsignificant odds ratio of 0.28 (95% CI 0.03, 2.97) was observed. Neither trial report included a procedure to guarantee allocation concealment, and sensitivity analyses were not conducted.

Only one trial of 18 weeks duration permitted a comparison of lower dose rosuvastatin 5 to 10 mg/day in combination with fenofibrate 200mg/day with higher dose rosuvastatin 40 mg/day monotherapy in 166 evaluable participants (Table 21; Appendix F, Table F-9).125 All participants on this trial had diabetes mellitus at baseline and required intensive lipid lowering therapy.125 In this study, participants on combination therapy received fixed doses of medications and participants on monotherapy had their medication dose increased every six weeks if LDL-c cholesterol remained above 50 mg/dL. The estimable odds ratio (fibrate plus statin combination compared with monotherapy) for this trial, based upon two deaths, was 0.46 (95% CI 0.03, 7.57).

One multicenter, non-randomized, controlled, 36 week trial compared fluvastatin 80mg/day plus gemfibrozil 1200 mg/day with fluvastatin 20, 40 or 80 mg/day in a conditional dose titration. Eleven 11 deaths were reported in 1077 evaluable participants with or without CHD, with triglycerides above 400 mg/dL and baseline mean LDL-c of 186 mg/dL.87 A single death was reported among 162 participants receiving combination therapy, while for monotherapy the deaths were 1/77 participants receiving fluvastatin 20mg/day, 4/237 receiving fluvastatin 40 mg/day, and 5/601 receiving fluvastatin 80 mg/day. No other outcome of interest was reported (Table 22).

##### Fatal myocardial infarction

Two trials in 194 evaluable participants reported one fatal MI. One 52 week trial, in 48 participants, compared fluvastatin 80 mg/day and fenofibrate 200 mg/day with fluvastatin 80 mg/day monotherapy in participants with combined hyperlipidemia, type II diabetes mellitus and coronary heart disease. No fatal myocardial infarction was reported.123 Another 12 week trial in 146 evaluable participants reported one fatal myocardial infarction in a participant receiving statin monotherapy therapy, yielding an nonsignificant odds ratio for fatal myocardial infarction of 0.31 (95% CI 0.01, 7.77).134 None of the trials comparing lower dose fibrate plus statin combination therapy with a higher dose of the same statin monotherapy reported fatal myocardial infarction (Table 21; Appendix F, Table F-9).

##### Myocardial infarction and acute coronary syndrome

A single trial with a followup of 52 weeks on 48 evaluable participants comparing fluvastatin 80 mg/day plus fenofibrate 200 mg/day with fluvastatin 80 mg/day monotherapy in participants with combined hyperlipidemia, type II diabetes mellitus and coronary heart disease reported no occurrence of myocardial infarction (including non-fatal myocardial infarction) or acute coronary syndrome (Table 21; Appendix F, Table F-9).123

##### Serious Adverse Events

Two trials in 652 evaluable participants reported the proportion of participants experiencing serious adverse events (Table 21; Appendix F, Table F-9).120,123 In the 52 week trial described above Derosa et al reported no serious adverse events in 48 participants requiring intensive lipid lowering therapy.123 Another trial of 12 weeks duration, comparing simvastatin (20 mg/day) and fenofibrate (200 mg/day) with simvastatin (20 mg/day) monotherapy in 604 participants reported 17 serious adverse events and a nonsignificant odds ratio (combination therapy versus monotherapy) of 1.2 (95% CI 0.42, 3.46) (Table 21).120

##### Cancer

There was no evidence for the outcome of cancer.

### Key Question 2: Do these regimens differ in reaching LDL-c targets (or other surrogate markers), short-term side effects, tolerability, and/or adherence?

#### Overview of Included Studies

Eleven trials, none of crossover design, randomizing 1991 participants compared statin plus fibrate-statin combinations with statin monotherapy and reported one or more surrogate efficacy or harms outcomes other than serious adverse events and cancer [Table 3; Appendix F, Table F-10 to F-16].50,120,123,125,134,145,160,161,188,192,195 Three trials provided information on participants‘ descent,120,123,125 with 90 to 100 percent of participants of European descent, 2.8 percent of African descent, and 6.5 percent of Hispanic descent. Trial duration ranged from six to 104 weeks, with an average of 32 weeks. No trial was conducted exclusively in a particular gender, and on average 40 percent of participants were female (range 11 to 58 percent). The average of mean ages of participants was 57 years (range of mean age 49 to 60 years). Five trials recruited outpatients,50,125,134,188,192 one trial recruited inpatients,195 and five trials did not report recruitment setting. The mean Jadad score was 2 (range 1 to 3) and two trials had adequate allocation concealment 120,160 Five trials recruited participants requiring intensive lipid lowering treatment, because of established vascular disease and/or diabetes mellitus and/or baseline LDL--c above 190 mg/dL.123,125,145,161,195 These five trials randomized 598 participants.

Across trials, participants were of heterogeneous characteristics including those with familial combined hypercholesterolemia,50,120,161,188,192 diabetes mellitus,125,145,161 established vascular disease and/or CHD risk equivalent and/or diabetes mellitus,123 and prior statin exposure.120,123,145 There was one trial exclusively in participants with metabolic syndrome.160 Most trials excluded participants with triglycerides above 300 to 600 mg/dL, patients with recent or unstable vascular disease, uncontrolled diabetes mellitus and hypertension, liver and muscle disease or high ALT, AST and CPK, and impaired renal function. No trial reported employing a fibrate-statin combined pill.

#### LDL-c Targets and Other Surrogate Markers

Comparing statin plus fibrate versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants reaching LDL-c ATPIII goals

Two trials in 240 evaluable participants reported 197 (82 percent) participants reaching the ATP III LDL-c targets. Both trials were conducted in participants requiring intensive lipid lowering therapy, with followup durations of 18 and 24 weeks (Table 23; Appendix F, Table F-10). No consistent trend was observed and significant heterogeneity prevented data being pooled (I2= 84 percent) (Appendix G, Figure G-45). The 24 week trial, in 80 participants compared atorvastatin 20 mg/day and fenofibrate 200 mg/day with atorvastatin 20 mg/day in participants with combined hyperlipidemia and type II diabetes mellitus, and had a significant odds ratio of 9.75 (95% CI 1.16, 82.11) favoring combination therapy.161 In contrast, the 18 week trial comparing rosuvastatin 5 to 10 mg/day plus fenofibrate 200mg/day with rosuvastatin 40 mg/day monotherapy in 163 evaluable participants with diabetes mellitus, showed a nonsignificant odds ratio of 0.49 (95% CI 0.20, 1.22).125 Only the latter trial permitted a comparison of lower dose statin plus fenofibrate with higher dose monotherapy using the same statin, or provided data for this comparison in those requiring intensive lipid lowering therapy.125 In this study participants on combination therapy received fixed doses of medications and participants receiving monotherapy had their medication dose increased every six weeks if LDL-c cholesterol remained above 50 mg/dL. All participants had diabetes mellitus at baseline (Appendix G, Figure G-45).

##### LDL-c, percentage mean change from baseline

Three trials of 12 to 18 weeks duration randomizing 904 evaluable participants yielded relevant data but because of substantial statistical heterogeneity (I2 = 82 percent) data were not pooled (Table 24; Appendix G, Figure G-46).120,125,145 One trial in a North America population, 90 percent of European descent, with prior use of statins showed a statistically significant difference in means of −5.4 percent (95% CI −8.39, −2.41) in favor of the statin plus fenofibrate combination.120 Results were similar, but not statistically significant, in two trials exclusively in participants requiring intensive lowering therapy because of diabetes mellitus, with a pooled mean difference of 4.82 percent (95% CI −0.35, 9.99) (Appendix G, Figure G-47).125,145 Across the three trials, only one permitted comparison of lower dose rosuvastatin (10 mg/day) plus fenofibrate (200mg/day) with higher dose rosuvastatin (40 mg/day) monotherapy in 104 evaluable participants.125 A nonsignificant mean difference of 4.5 percent (95% CI −4.1, 13.1) was observed (Table 24; Appendix F, Table F-11).

##### HDL-c, percentage mean change from baseline

Three trials with followup duration of 12 to 18 weeks in 964 evaluable participants yielded a statistically significant mean difference of 7.44 percent (95% CI 4.95, 9.92) (Table 25; Appendix F, Table F-12) favoring the statin plus fenofibrate combination.120,125,145 Two trials were exclusively in participants with diabetes mellitus,125,145 and two were in participants with prior use of statins.120,145 All three trials compared identical statins in combination and monotherapy, and all but one125 investigated simvastatin 20 mg/day. Doses of fenofibrate were 200 mg/day. Pooled mean differences for the two trials conducted in participants requiring intensive lipid lowering therapy were 5.18 percent (95% CI 1.23, 9.11) (Table 19).125,145 One trial permitted comparison of lower dose statin in combination therapy with higher dose monotherapy using the same statin.125 In the trials in participants with diabetes mellitus, fixed dose treatment with rosuvastatin 10 mg/day plus fenofibrate 200 mg/day was compared with conditionally dosed rosuvastatin up to 40 mg/day, over 18 weeks. LDL-c mean percentage difference between treatments was 4.81 percent (95% CI −0.56, 10.18) (Table 25).

Table 19

Evidence addressing key question 2 for statin plus fibrate versus statin monotherapy comparison

Outcomes | Extractable data availability | Key points of evidence synthesis
Participants attaining ATP III LDL-c targets | Yes | One trial using a higher dose statin monotherapy in participants with diabetes mellitus showed no significant results. Another study comparing the same statin and same dose in combination therapy and monotherapy favored combination therapy.
LDL-c | Yes | Two trials using the same statin in combination and monotherapy, one of them with higher statin dose monotherapy, in participants with diabetes mellitus showed no significant results.
HDL-c | | Three trials using the same statin, one of them with higher statin dose monotherapy, showed a significant difference favoring the fibrate plus statin combination.
TC:HDL ratio | | One trial used higher dose statin monotherapy in participants with diabetes mellitus. No significant difference was observed.
Measure(s) of atherosclerosis | No
Treatment Adherence | No
Participants experiencing at least one adverse event | Yes | Three trials using the same statin, one of them with higher dose statin monotherapy reported 90 adverse events in 362 evaluable participants. Data was heterogeneous and not pooled.
Withdrawal due to adverse events | Yes | Five trials, one comparing different statins, and one using higher dose statin monotherapy, reported 41 withdrawals due to AEs in 1269 evaluable participants. Data was heterogeneous and not pooled.
Elevated AST and/or ALT > 3 times ULN and/or hepatitis | Yes | Four trials, one comparing various statins, and two comparing with higher dose statin monotherapy, reported 11 episodes of myalgia in 841 evaluable participants. No significant difference was observed.
Myalgia | Yes | No significant difference was noted across statin plus fibrate combination compared with statin monotherapy, including comparisons of lower dose statin combination with higher doses of the same statin monotherapy in six trials
CPK > 10 times ULN | Yes | Five 12 to 24 week trials in 1199 evaluable participants reported one event. No significant difference was observed.
Rhabdomyolysis (investigator defined) | Yes | Three 12 week trials in 951 evaluable participants reported no events.

Abbreviations: ALT = alanine transferase, AST = aspartate transferase, ATP III = Third Adult Treatment Panel of the National Cholesterol Education Program, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, TC = total cholesterol

##### TC:HDL-c ratio, percentage mean change from baseline

A single trial in participants requiring intensive lipid lowering therapy because of diabetes mellitus compared fixed lower dose rosuvastatin 10 mg/day in combination with fenofibrate (200mg/day) with conditionally dosed rosuvastatin up to 40 mg/day monotherapy, in 104 evaluable participants. The nonsignificant mean difference was −2.7 percent (95% CI −10.46, 5.06) (Table 26; Appendix F, Table F-13).125

#### Harms and Treatment Adherence

Comparing statin plus fibrate versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants with at least one adverse event

Three trials of 12 to 52 weeks duration in 362 evaluable participants reported 90 adverse events, but because of substantial statistical heterogeneity (I2 = 60 percent) data were not pooled (Table 27). No consistent trend was observed. One 52 week trial compared fluvastatin 80 mg/day plus fenofibrate 200 mg/day with fluvastatin 80 mg/day in 48 evaluable participants of European descent with established coronary artery diseases and prior use of statins. The authors reported a nonsignificant odds ratio of 1.43 (95% CI 0.22, 9.44) favoring monotherapy based on 5 events.123 A second trial in 168 participants with followup duration of 18 weeks, comparing rosuvastatin 5 to 10 mg/day plus fenofibrate 200mg/day with rosuvastatin 40 mg/day monotherapy in participants with diabetes mellitus, yielded a nonsignificant odds ratio of 0.73 (95% CI 0.34, 1.57) favoring monotherapy based on 38 events.125 A third 12 week trial comparing pravastatin 40 mg/day plus gemfibrozil 1200 mg/day with pravastatin 40 mg/day in 146 evaluable participants yielded a significant odds ratio of 2.42 (95% CI 1.18, 4.99) favoring monotherapy based on 47 events (Appendix F, Table F-16).134 As described here, only one of the described trials compared lower dose statin plus fenofibrate with higher dose monotherapy.125

##### Participants withdrawing due to adverse events

Five trials of 12 to 52 weeks duration in 1269 evaluable participants reported 41 withdrawals due to adverse events, but because of substantial statistical heterogeneity (I2 = 56 percent) data were not pooled (Table 27). With low event rates across trials, no trial showed a significant difference in odds between groups. Point estimates for odds ranged from 0.29 to 7.22. One trial, with the smallest sample size, did not register any event over 24 weeks of followup. Although no significant trend in results was observed across most of the prestated heterogeneity covariates, Durrington et al.‘s125 was the only trial demonstrating a nonsignificantly higher proportion of participants withdrawing due to adverse events in a monotherapy arm that employed rosuvastatin 40 mg/day (Appendix F, Table F-16).

##### Participants with AST and/or ALT above 3 times the upper limit of normal, and/or hepatitis

In four trials of 18 to 54 weeks, in 841 evaluable participants, 11 cases of elevated AST/ALT above three times the upper limit were reported (Table 27; Appendix F, Table F-16).50,125,160,161 One trial, in 80 participants, compared atorvastatin 20 mg/day plus fenofibrate 200 mg/day with atorvastatin 20 mg/day in participants with combined hyperlipidemia and diabetes mellitus. No participants had any element of the composite outcome during 24 weeks of followup.161 Three trials of 18 to 54 weeks duration, in 761 evaluable participants, could be meta-analyzed and yielded a nonsignificant pooled odds ratio of 2.38 (95% CI 0.41, 14.0) favoring monotherapy based on 11 events (Table 27).50,125,160 In a single trial in 168 evaluable participants comparing rosuvastatin plus fibrate with higher dose rosuvastatin monotherapy, six participants in the combination therapy experienced AST/ALT above three times the upper limit of normal, yielding a nonsignificant estimable odds ratio of 6.35 (95% CI 0.35, 114.85) favoring monotherapy (Table 27).

##### Participants with myalgia

In six trials of 12 to 104 weeks, 32 cases of myalgia were reported in 1439 evaluable participants (Table 27; Appendix F, Table F-16). One trial comparing atorvastatin 20 mg/day plus fenofibrate 200 mg/day with atorvastatin 10 mg/day in two of its four arms, reported no cases of myalgia among participants during 12 weeks followup.195 Data on 1389 evaluable participants could be meta-analyzed without evident heterogeneity (Table 27).50,120,125,134,188,195 A nonsignificant odds ratio of 1.17 (95% CI 0.52, 2.62) was observed, and asymmetry was not evident on the funnel plot (Appendix G, Figure G-49). Two trials using different statins permitted a comparison of lower dose statin plus fenofibrate with higher dose monotherapy using the same statin.125,195 One trial compared fixed dosed rosuvastatin 5 to 10 mg/day plus fenofibrate 200mg/day with a conditionally titrated dose of rosuvastatin 40 mg/day monotherapy in 168 evaluable participants with diabetes mellitus, yielding an estimable nonsignificant odds ratio of 1.39 (95% CI 0.14, 13.71) based on four cases of myalgia (Table 27) 125 Another trial compared lower dose simvastatin 20 mg/day plus fenofibrate (200 mg/day) with higher dose simvastatin (40 mg/day) monotherapy in 50 evaluable participants of South Asian descent, yielding a nonsignificant estimable odds ratio of 0.18 (95% CI 0.01, 4.04) based on two cases of myalgia (Table 27).195

##### Participants with CPK above 10 times the upper limit of normal

Five trials in 1,199 evaluable participants reported one event of CPK above 10 times the upper limit of normal (Table 27; Appendix F, Table F-16). Four trials reported no events in participants during 12 to 24 weeks followup.125,134,145,161 One trial of 12 weeks duration in 605 evaluable participants reported one event of elevated CPK and a nonsignificant estimable odds ratio of 1.51 (95% CI 0.06, 37.22) (Table 27).120 Lower dose rosuvastatin plus fibrate was compared with higher dose monotherapy in one trial with no events.125

##### Participants with rhabdomyolysis

Three trials in 951 evaluable participants reported no events of rhabdomyolysis during a followup of 12 weeks (Table 27; Appendix F, Table F-16).120,134,145

### Key Question 3: Compared with higher-dose statins, and to one another, do combination regimens differ in benefits and harms within subgroups of patients?

Table 20

Availability of evidence addressing key question 3 for statin plus fibrate versus statin monotherapy comparison

[table image]

Abbreviations: HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, TC = total cholesterol, TG = triglycerides

#### Clinical Outcomes

Comparing statin plus fibrate versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### All-cause mortality

###### Participants with diabetes mellitus

One trial with estimable data on all-cause mortality permitted the comparison of lower dose rosuvastatin 5 to 10 mg/day plus fenofibrate 200 mg/day with higher dose rosuvastatin 40 mg/day monotherapy in 166 evaluable participants with diabetes mellitus.125 Those on combination therapy received fixed doses of medications, while participants on monotherapy had their medication dose increased every six weeks if LDL-c cholesterol remained above 50 mg/dL. A nonsignificant odds ratio of 0.46 (95% CI 0.03, 7.57) was observed (Table 21; Appendix F, Table F-9). No studies reported data on vascular death for participants with diabetes mellitus.

#### LDL-c Targets and Other Surrogate Markers

Comparing statin plus fibrate versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants attaining ATP III LDL-c goals

###### Participants with diabetes mellitus

In two trials of 18 to 24 weeks duration, in 240 evaluable participants, 197 participants reaching ATP III LDL-c targets (Table 23; Appendix F, Table F-10). No consistent trend was observed and significant heterogeneity prevented data being pooled (I2 = 84 percent) (Appendix G; Figure G-45). The 24-week trial in 80 participants compared atorvastatin 20 mg/day plus fenofibrate 200 mg/day with atorvastatin 20 mg/day in participants with combined hyperlipidemia and type II diabetes mellitus, yielding a significant estimable odds ratio of 9.75 (95% CI 1.16, 82.11) favoring combination therapy.161 In contrast, a 18-week trial comparing rosuvastatin 5 to 10 mg/day plus fenofibrate 200mg/day with rosuvastatin 40 mg/day monotherapy in 163 evaluable participants with diabetes mellitus, showed a nonsignificant odds ratio of 0.50 (95% CI 0.20, 1.24) (forest plot).125 The latter trial compared lower dose rosuvastatin plus fenofibrate with higher dose rosuvastatin monotherapy (Table 23).125

##### LDL-c, percentage mean change from baseline

###### Participants with diabetes mellitus

Two trials of 12 to 18 weeks duration, in 304 evaluable participants, yielded a pooled mean difference of 4.82 percent (95% CI −0.35, 9.99) (Table 24; Appendix F, Table F-11; Appendix G, Figure G-48).125,145 One trial compared lower dose rosuvastatin plus fenofibrate with higher dose rosuvastatin monotherapy, yielding a nonsignificant mean difference of 4.5 percent (95% CI −4.10, 13.10) (Figure G-48, Table 24).125

##### HDL-c, percentage mean change from baseline

###### Participants with diabetes mellitus

Two trials of 12 to 18 weeks in 364 evaluable participants yielded a significant pooled mean difference of 5.17 percent (95% CI 1.23, 9.11) (Table 25; Appendix F, Table F-12).125,145 One trial compared lower dose rosuvastatin plus fenofibrate with higher dose rosuvastatin monotherapy, yielding a nonsignificant mean difference of 4.81 percent (95% CI −0.56, 10.18) (Table 25).125

##### TC:HDL-c ratio, percentage mean change from baseline

###### Participants with diabetes mellitus

One trial comparing lower dose rosuvastatin 10 mg/day plus fenofibrate 200mg/day with higher dose rosuvastatin 40 mg/day monotherapy in 104 evaluable participants yielded a nonsignificant mean difference of −2.7 (95% CI −10.46, 5.06) (Table 26; Appendix F, Table F-12).125

##### Non-HDL-c, percentage mean change from baseline

###### Participants with diabetes mellitus

One trial comparing the simvastatin 20 mg/day plus fenofibrate 160mg/day with simvastatin 20 mg/day monotherapy in 200 evaluable participants yielded a nonsignificant mean difference of 1.80 (95% CI −3.01, 6.61) (Appendix F, Table F-14).145

##### Triglycerides, percentage mean change from baseline

###### Participants with diabetes mellitus

One trial comparing lower dose rosuvastatin 10 mg/day plus fenofibrate 200mg/day with higher dose rosuvastatin 40 mg/day monotherapy in 154 evaluable participants yielded a significant mean difference of −13.57 (95% CI −24.16, −2.98) favoring fibrate-statin combination therapy.125

#### Strength of Evidence

The strength of the available evidence was assessed as GRADE (Grading of Recommendations Assessment, Development and Evaluation) 225 for the key outcomes all-cause mortality, vascular death, serious adverse events and achieving ATP-III target LDL-c. Results generated using the GRADEpro software presented in Tables H-12 to H-16 (Appendix H) are summarized as follows:

1. Based on a single study in participants requiring intensive lipid lowering therapy, GRADE was “very low” for all cause mortality and participants reaching ATP III LDL-c goals for the combination of lower dose statin plus fenofibrate compared to higher dose statin (Appendix H, Table H-12).
2. Based on studies in participants requiring intensive lipid lowering therapy and comparing the combination of any dose statin plus fibrate to any dose statin, GRADE was “very low” for all cause mortality (1 trial), serious adverse events (1 trial) and participants reaching ATP III LDL-c goals (2 trials) (Appendix H, Table H-13).
3. Based on studies in participants with diabetes mellitus and comparing the combination of any dose statin plus fibrate to any dose statin,, GRADE was “very low” for all cause mortality (1 trial) and participants reaching ATP III LDL-c goals (2 trials) (Appendix H, Table H-14).
4. Based on a one study in participants followed up for more than 24 weeks, GRADE was “very low” for all cause mortality, serious adverse events and participants reaching ATP III LDL-c goals for the combination of any dose statin plus fibrate compared to any dose statin (Appendix H, Table H-15).
5. Based on studies in participants regardless of baseline risk and comparing the combination of any dose statin plus fibrate to any dose statin, GRADE was “very low” for all cause mortality (3 trials), serious adverse events (2 trials) and participants attaining ATP III LDL-c goals (2 trials) (Appendix H, Table H-16).

### Evidence Summary Tables: Statin Plus Fibrate Combination Therapy versus Statin Monotherapy

Table 21

Quantitative syntheses of longer-term outcomes data (clinical, serious adverse events and cancer) for fibrate-statin combination therapy compared with statin monotherapy

| Number of trials reporting outcome | Number of participants in relevant intervention groups | Number of participants with events | Odds ratio | Lower CI | Upper CI
All-cause mortality
All trials125,134,188 | 3 | 339 | 3 | 0.28^*^ | 0.03 | 2.97
Rosuvastatin
Lower dose statin in combination therapy versus higher dose monotherapy125 Participants requiring intensive lipid lowering therapy, due to diabetes mellitus125 | 1 | 166 | 2 | 0.46 | 0.03 | 7.57
Fatal Myocardial Infarction
All trials123,134 | 2 | 194 | 1 | 0.31 | 0.01 | 7.77
Myocardial Infarction
Non-fatal myocardial infarction123 | 1 | 48 | 0
Any myocardial infarction123 | 1 | 48 | 0
Acute coronary syndrome
All trials123 | 1 | 48 | 0
Serious Adverse Event(s)
All trials120,123 | 2 | 652 | 17 | 1.20 | 0.42 | 3.46

* Peto Odds Ratio; Abbreviation: CI = 95% confidence interval

Table 22

Summary of non-randomized evidence on fluvastatin plus gemfibrozil combination therapy versus gemfibrozil monotherapy

Trial | Design Duration Downs and Black score | Patients (LDL-c mg/dL) | Monotherapy Dose (mg/day) | Combination Therapy Dose (mg/day) | Results | Limitations | Applicability | Conclusion
van Dam (2001)87 Multicenter/Europe Pharmaceutical Industry | CCT Conditional dose titration and fibrate addition to statin therapy over 9 months Stable doses for 1 year 15/28 | 1501 (N evaluable = 1077) outpatients with or without CHD TG < 400 mg/dL Mean baseline LDL-c = 186 mg/dL | Fluvastatin (20, 40 and 80 mg) | Fluvastatin plus ( 80); Gemfibrozil (1200) | All-cause mortality: F20 = 1/77 F40 = 4/237 F80 = 5/601 F80+G1200 = 1/162 Other clinical outcomes of interest, SAE and cancer not reported | Unlike statin monotherapy groups, patients on combination therapy had combined hyperlipidemia (additional hypertriglyceridemia). Those on statin monotherapies differed in LDL-c target goals and degree of dysplipidemia. Study was not powered for the outcome of mortality | Narrow eligibility criteria, lack of reporting of important clinical outcomes, 1 year stable dose followup, and low event rates are suggestive of low applicability | Results are inconclusive given low event rate and lack of statistical significance

Abbreviations: CCT = controlled clinical trial, F = fluvastatin, G = gemfibrozil, LDL-c = low density lipoprotein cholesterol, N = number, SAE = serious adverse events, TG = triglycerides

Table 23

Quantitative syntheses of participants attaining ATP III LDL-c targets data, for fibrate-statin combination therapy compared with statin monotherapy

| Number of trials reporting outcome | Number of participants in relevant treatment groups | Number of participants with events | Odds ratio | Lower CI | Upper CI
Relative probability of attaining ATPIII LDL-c goal
All trials All participants with diabetes mellitus Participants requiring intensive lipid lowering therapy125,161 | 2 | 240 | 197 | - | - | -
Rosuvastatin
Lower dose statin in combination therapy versus higher dose monotherapy125 | 1 | 163 | 126 | 0.49 | 0.20 | 1.22

Abbreviations: ATP III = Third Adult Treatment Panel of the National Cholesterol Education Program, CI = 95% confidence interval, LDL-c = low density lipoprotein cholesterol

Table 24

Quantitative syntheses of LDL-c data for fibrate-statin combination therapy compared with statin monotherapy

| Number of trials | Number of participants in relevant treatment groups | Point Estimate | Lower CI | Upper CI
Difference in mean LDL-c percentage change from baseline (%)
All trials120,125,145 | 3 | 904 | - | - | -
Lower dose statin in combination versus higher dose monotherapy125 | 1 | 104 | 4.50 | −4.10 | 13.10
Participants in need of intensive lipid lowering therapy, all with diabetes mellitus125,145 | 2 | 304 | 4.82 | −0.35 | 9.99

Abbreviations: CI = 95% confidence interval, LDL-c = low density lipoprotein cholesterol

Table 25

Quantitative syntheses of HDL-c data, for fibrate-statin combination therapy compared with statin monotherapy

| Number of trials | Number of participants in relevant treatment groups | Point Estimate | Lower CI | Upper CI
Difference in mean HDL-c percentage change from baseline (%)
All trials 120,125,145 | 3 | 964 | 7.44 | 4.95 | 9.92
Rosuvastatin
Lower dose statin in combination therapy versus higher dose monotherapy | 1 | 164 | 4.81 | −0.56 | 10.18
Participants requiring intensive lipid lowering therapy, all with diabetes mellitus 125 Participants in need of intensive lipid lowering therapy, all with diabetes mellitus 125,145 | 2 | 364 | 5.18 | 1.23 | 9.12

Abbreviations: CI = 95% confidence interval, HDL-c = high density lipoprotein cholesterol

Table 26

Quantitative syntheses of total cholesterol:HDL-c ratio data, for fibrate-statin combination therapy compared with statin monotherapy

| Number of trials | Number of participants in relevant treatment groups | Point Estimate | Lower CI | Upper CI
Difference in mean TC:HDL-c percentage change from baseline (%)
All trials
Rosuvastatin
Lower dose statin in combination therapy versus higher dose monotherapy125 | 1 | 104 | −2.70 | −10.46 | 5.06
All participants with diabetes mellitus
Participants in need of intensive lipid lowering therapy125

Abbreviations: CI = 95% confidence interval, HDL-c = high density lipoprotein cholesterol, TC = total cholesterol

Table 27

Quantitative syntheses of short-term harms and treatment adherence data for fibrate-statin combination therapy compared with statin monotherapy

| Number of trials reporting outcome | Number of participants in relevant treatment groups | Number of participants with events | Odds ratio | Lower CI | Upper CI
Participants with adverse events
All trials123,125,134 | 3 | 362 | 90 | - | - | -
Rosuvastatin
Lower dose statin in combination therapy versus higher dose monotherapy125 | 1 | 168 | 38 | 0.73 | 0.34 | 1.57
Withdrawals due to adverse events
All trials50,120,125,134,161 | 5 | 1269 | 41 | - | - | -
Rosuvastatin
Lower dose statin in combination therapy versus higher dose monotherapy125 | 1 | 168 | 5 | 0.29 | 0.05 | 1.82
AST and/or ALT ≥ times the upper limit of normal, and/or hepatitis
All trials50,125,160,161 | 4 | 841 | 11 | 2.38 | 0.41 | 14.00
Rosuvastatin
Lower dose statin in combination therapy versus higher dose monotherapy125 | 1 | 168 | 6 | 6.35 | 0.35 | 114.85
Myalgia
All trials50,120,125,134,188,195 | 6 | 1439 | 31 | 1.17 | 0.52 | 2.62
Rosuvastatin
Lower dose statin in combination therapy versus higher dose monotherapy125 | 1 | 168 | 4 | 1.39 | 0.14 | 13.71
Simvastatin
Lower dose statin in combination therapy versus higher dose monotherapy195 | 1 | 50 | 2 | 0.18 | 0.01 | 4.04
CPK ≥ 10 times the upper limit of normal
All trials120,125,134,145,161 | 5 | 1199 | 1 | 4.49 | 0.07 | 286.36
Rosuvastatin
Lower dose statin in combination therapy versus higher dose monotherapy125 | 1 | 168 | 0 | - | - | -
Rhabdomyolysis (investigator defined)
All trials120,134,145 | 3 | 951 | 0 | - | - | -

Abbreviations: ALT = alanine transaminase, AST = aspartate transaminase, CI = 95% confidence interval, CPK = creatinine phosphokinase

## Statin Plus Niacin Combination Therapy Versus Statin Monotherapy

### Overview of Included Studies

A total of 16 randomized controlled trials evaluated relative efficacy and/or harms of the combination of niacin plus a statin compared with statin monotherapy, in a total of 2,731 participants (Table 3; Appendix F, Table F-17 to F-23). None of the included non-randomized studies addressed this particular comparison. Nine of the 16 randomized trials had more than one associated journal published or FDA report (Table 5). Data reported in the two FDA reports104,105 are similar to data presented in two published manuscripts.128,182 The similarities included the inclusion/exclusion criteria, number of patients randomized and outcomes. However, since no direct connection could be found in the reports to confirm that they are the same trial, they were included as separate trial reports.

Ten trials were conducted in multiple centers,49,104,105,128,139,150,155,170,171,182 and six in a single center.162,183,184,189,196,197 There were no trials exclusively in females, or participants of Asian, Hispanic, and/or African descent.

Reporting of participants’ ethnic background was as follows:

- 10 trials reported a mean of 85 percent of participants of European descent (range 75 to 94 percent)
- Three trials reported a mean of 3 percent of participants of Asian descent (range 2 to 4 percent)
- Six trials reported a mean of 8 percent of participants of Hispanic descent (range 0 to 22 percent)
- Four trials reported a mean of 9 percent of participants of African descent (range 5 to 15 percent)

Trial duration ranged from six to 52 weeks, with an average of 23 weeks. On average 35 percent of participants were women (range 7 to 50 percent). The average of mean ages of participants was 58 years (range of mean age 51 to 67 years). Nine trials recruited solely from outpatient settings,49,104,105,128,139,155,183,196,197 while seven did not report recruitment setting.

Of these sixteen trials, only three were exclusively in participants requiring intensive lipid lowering therapy (i.e. participants with established vascular disease and/or cerebro-vascular disease and/or diabetes mellitus and/or baseline LDL-c above 190 mg/dL).162,196,197. Additionally, one trial provided data on the subgroup for participants with established vascular disease.49

The mean Jadad score was 2.6 (range, 1 to 5). Five trial reports described an appropriate method of randomization,104,105,171,183,196 while seven reported an appropriate method of double blinding.104,105,128,150,171,182,196 Two of these trials with an appropriate method of double blinding added immediate release Niacin 50mg/day in the monotherapy arms to protect the blinding.150,171 Allocation concealment was reported to be adequate in four trials.104,105,171,196

Twelve of sixteen trials were partially or completely sponsored by the pharmaceutical industry,49,128,139,150,155,162,170,171,182–184,197 while this was not reported or unclear for three trials.104,105,189

All trials were conducted in North America.

### Key Question 1: For patients who require intensive lipid-modifying therapy, what are the comparative long-term benefits, and rates of serious adverse events of coadministration of different lipid-modifying agents (i.e. a statin plus another lipid-modifying agent) compared with higher dose statin monotherapy?

Table 28

Evidence addressing key question 1 for statin plus niacin versus statin monotherapy comparison

Outcomes | Evidence availability | Key points of evidence synthesis
All-cause mortality | Yes | No significant difference was observed for the outcome in trials in mixed populations (OR 1.08; 95% CI 0.17, 6.72) or in participants requiring intensive lipid lowering therapy (OR 1.84; CI 0.16, 20.76)
Vascular death | Yes | No significant difference was observed for the outcome in trials in mixed populations (OR 0.53; 95% CI 0.03, 8.64) or in participants requiring intensive lipid lowering therapy (no deaths occurred in either group)
Fatal myocardial infarction (MI) | Yes | No significant difference was observed for the outcome (OR 4.64; 95% CI 0.08, 283.78)
Non-fatal MI | No
Any or unspecified MI | No
Acute coronary syndrome (ACS) (encompassing unstable angina or acute MI) | Yes | No significant difference was observed for the outcome in (OR 0.91; 95% CI 0.12, 6.62)
Any cerebrovascular event | No
Hemorrhagic stroke | No
Ischemic stroke | No
Any or unspecified stroke | Yes | No significant difference was observed for the outcome in one trial (OR 0.12; 95% CI 0.00, 6.21)
Transient ischemic attack (TIA) | No
Carotid endarterectomy (CEA) | No
Percutaneous coronary interventional procedure (PCI) | Yes | No significant difference was observed for the outcome in one trial (OR 3.78; 95% CI 0.41, 34.68)
Coronary artery bypass graft procedure (CABG) | No
Any or unspecified revascularization procedure | No
Serious adverse events | Yes | No significant difference was observed for the outcome (OR 1.29; 95% CI 0.44, 3.80)
Cancer | Yes | No significant difference was observed for the outcome (OR 0.10; 95% CI 0.00, 2.20)

Abbreviations: ACS = acute coronary syndrome, CABG = coronary artery bypass graft, CEA = carotid endarterectomy, MI = myocardial infarction, PCI = percutaneous coronary intervention, SAE = serious adverse event

#### Study Design and Population Characteristics

A total of eight trials, one of crossover design, randomizing 1481 participants compared niacin plus a statin with statin monotherapy and reported one or more of clinical outcomes, serious adverse events and cancer (Table 31; Appendix F, Table F-17).104,105,128,150,170,171,196,197 There were no trials exclusively in females or participants of Asian, Hispanic, or African descent.

Reporting of participants’ ethnic background was as follows:

- Six trials reported a mean of 84 percent of participants of European descent (range 75 to 90 percent)
- Three trials reported a mean of 3 percent of participants of Asian descent (range 2 to 4 percent)
- Five trials reported a mean of 9 percent of participants of Hispanic descent (range 1 to 22 percent)
- Three trials reported a mean of 8 percent of participants of African descent (range 5 to 13 percent)

Trial duration ranged from 12 to 52 weeks with an average of 28 weeks. Although no trial totally excluded females, on average 33 percent of participants were women (range 7to 49 percent). The average of mean ages of participants was 59 years (range of mean age 53 to 67 years). Five trials recruited outpatients,104,105,128,196,197 while three trials did not report recruitment setting. The mean Jadad score was 3.4 (range, 1 to 5) and four trials had adequate allocation concealment.104,105,171,196

Of these eight trials, only three were exclusively in participants requiring intensive lipid lowering therapy (i.e. participants with established vascular disease and/or cerebro-vascular disease and/or diabetes mellitus and/or baseline LDL-c above 190 mg/dL).162,196,197. Additionally, one trial provided data on the subgroup for participants with established vascular disease.49

#### Long-Term Efficacy, Serious Adverse Events, and Cancer

Comparing statin plus niacin versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### All-cause mortality

Incidence of all cause mortality for participants requiring intensive lipid-modifying therapy (participants with established vascular disease), using various statins and doses, was reported for one trial with a 52-week followup period, with adequate allocation concealment (Table 31).196 There were no statistically significant differences between the incidence in the two groups, with an odds ratio of 1.84 (95% CI 0.16, 20.76).

For all trials, using various statins and doses, all-cause mortality was reported for six trials,104,105,150,170,171,196 four of which were 24 weeks or longer in duration.105,150,171,196 Of these four trials, two provided analyzable data (Table 31; Appendix G, Figure G-50).105,196 Data from the other trials were not analyzable because no deaths were recorded during the followup period.104,150,170,171

In addition, four trials were considered to have adequate allocation concealment,104,105,171,196 three of which were 24 weeks or longer in duration.105,171,196 Two provided analyzable data.105,196 Pooling of these two trials demonstrated no significant differences in mortality between the two groups, with an odds ratio of 1.08 (95% CI 0.17, 6.72) based on five events.

There was no evidence for the comparative analysis of a specific lower dose statin in combination with niacin versus higher dose of the same statin monotherapy in all trial populations.

##### Vascular death

The incidence of vascular death was reported for one trial, for participants requiring intensive lipid-modifying therapy (Table 31) with an unclear form of allocation concealment and a followup duration of 12 weeks.197 Participants had established vascular disease and were receiving various statins and doses. No deaths were recorded during the followup period and so the outcome was not analyzable.

For all trials, using various statins and doses, vascular death was reported for two trials,128,197 one of which had a followup duration of 24 weeks or more (Table 31).128 Both trials had an unclear form of allocation concealment. One study had no analyzable data (no events in both groups),197 while the other demonstrated no statistically significant difference in the incidence between the two groups, with an odds ratio of 0.53 (95% CI 0.03, 8.64) based on two events.128

There was no evidence for the comparative analysis of a specific lower dose statin in combination with niacin versus higher dose of the same statin monotherapy in all trial populations.

##### Fatal myocardial infarction

In all trial populations, fatal myocardial infarction was reported for two trials,105,197 using various statins and doses; one of which had a followup duration of 28 weeks.105 Analyzable data was only provided for one trial,105 which demonstrated no statistically significant difference in the incidence between the two groups, with an odds ratio of 4.64 (95% CI 0.08, 283.78), based upon one event in both groups (Table 31).

There was no evidence for the comparative analysis of a specific lower dose statin in combination with niacin versus higher dose of the same statin monotherapy in all trial populations.

##### Any or unspecified stroke

Stroke was reported for only one trial with a followup duration of 52 weeks in participants using various statins and doses (Table 31).196 The study demonstrated no statistically significant difference in the incidence between the two groups, with an odds ratio of 0.12 (95% CI 0.00, 6.21) based upon one event in both groups.

There was no evidence for the comparative analysis of a specific lower dose statin in combination with niacin versus higher dose of the same statin monotherapy in all trial populations.

##### Acute coronary syndrome

In all trial populations, acute coronary syndrome was reported for one trial with a followup duration of 52 weeks in participants using various statins and doses (Table 31).196 The study demonstrated no statistically significant difference in the incidence between the two groups, with an odds ratio of 0.91 (95% CI 0.12, 6.62) based on four events in both groups.

There was no evidence for the comparative analysis of a specific lower dose statin in combination with niacin versus higher dose of the same statin monotherapy in all trial populations.

##### Percutaneous coronary intervention

Percutaneous coronary intervention was reported for one trial with a followup duration of 52 weeks in participants using various statins and doses (Table 31).196 The study demonstrated no statistically significant difference in the incidence between the two groups, with an odds ratio of 3.78 (95% CI 0.41, 34.68) based upon five events.

There was no evidence for the comparative analysis of a specific lower dose statin in combination with niacin versus higher dose of the same statin monotherapy in all trial populations.

##### Serious adverse events

In all trial populations, serious adverse events were reported for five trials,104,105,150,170,171 three of which had a followup duration of 28 weeks or more105,150,171 (Table 31; Appendix G, Figure G-51). Pooling of the trial data demonstrated no statistically significant difference in the incidence between the two groups based upon sixteen events (OR 1.29; 95% CI 0.44, 3.80). Furthermore, in the long-term trials,105,150,171 there was no statistically significant difference in the incidence of participants with a serious adverse event between the two groups, with an odds ratio of 1.00 (95% CI 0.26, 3.86) based on seven events.

There was no evidence for the comparative analysis of a specific lower dose statin in combination with niacin versus higher dose of the same statin monotherapy in all trial populations.

##### Cancer

In all trial populations, cancer was reported for one trial (Table 31).105 The study followed up 175 participants for 28 weeks. The data demonstrated no statistically significant difference in the incidence between the two groups, with an odds ratio of 0.10 (95% CI 0.00, 2.20) based upon two events.

There was no evidence for the comparative analysis of a specific lower dose statin in combination with niacin versus higher dose of the same statin monotherapy in all trial populations.

### Key Question 2: Do these regimens differ in reaching LDL-c targets (or other surrogate markers), short-term side effects, tolerability, and/or adherence?

Table 29

Evidence addressing key question 2 for statin plus niacin versus statin monotherapy comparison

Outcomes | Evidence availability | Key points of evidence synthesis
Patients attainting ATP III LDL-c targets | Yes | No significant difference was observed in trials in participants requiring intensive lipid lowering therapy (OR 1.51; 95% CI 0.56, 4.08). Results for participants from mixed populations were not pooled due to substantial heterogeneity.
LDL-c | Yes | Compared with monotherapy, no significant difference was observed for the outcome in trials in participants requiring intensive lipid lowering therapy (MD 0.00 %; 95% CI −6.51, 6.51). Results for participants from mixed populations were not pooled due to substantial heterogeneity.
HDL-c | Yes | A significant difference was observed for the outcome in trials comprising of participants requiring intensive lipid lowering therapy favoring combination therapy (MD 13.00 %; 95% CI 6.01, 20.00). Results for participants from mixed populations were not pooled due to substantial heterogeneity.
TC:HDL ratio | Yes | Data from one trial demonstrated significantly greater reduction favoring niacin plus statin combination therapy (MD −6.00 %; 95% CI −9.60, −2.40) in a mixed population.
Measure(s) of atherosclerosis | Yes | Niacin plus statin combination therapy was not significantly different from monotherapy in reducing carotid-intima media thickness
Treatment adherence | Yes | In one trial comparing niacin plus 10 mg rosuvastatin versus 40 mg rosuvastatin there was more favorable adherence to the combination medication (OR 0.40; 95% CI 0.19, 0.84). No significant difference in the incidence was observed in reports of treatment adherence with various statins and doses (OR 0.79; 95% CI 0.50, 1.27).
Total adverse events | Yes | In one trial comparing niacin plus rosuvastatin 10 mg/day versus rosuvastatin 40 mg/day there was better adherence to the combination medication (OR 1.94; 95% CI 0.79, 4.78). Results from trials with various statins and doses were not pooled due to substantial heterogeneity.
Withdrawal due to adverse events | Yes | The odds of withdrawal due to adverse events was significantly higher following niacin plus statin combination therapy than statin monotherapy (OR 2.38; 95% CI 1.63, 3.47).
Elevated serum AST and/or ALT > 3 times ULN and/or hepatitis | Yes | The incidence of these outcomes was similar (OR 1.39; 95% CI 0.36, 5.36).
Myalgia | Yes | Compared with monotherapy, in mixed populations the incidence of these outcomes was similar following niacin plus statin combination therapy than statin monotherapy (OR 0.45; 0.19, 1.07).
CPK > 10 times ULN | Yes | There was no reported incidence
Rhabdomyolysis | Yes | There was no reported incidence

Abbreviations: ALT = alanine transferase, AST = aspartate transferase, ATP III = Third Adult Treatment Panel of the National Cholesterol Education Program, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, TC = total cholesterol

#### Study Design and Population Characteristics

A total of fifteen trials, none of crossover design, randomizing 2677 participants compared niacin plus statin therapy with statin monotherapy and reported one or more of the following outcomes: participants reaching LDL-targets and/or other surrogate markers, short-term side effects, tolerability, and/or adherence to treatment (Table 32 to 37; Appendix F, Table F-18 to F-23).49,104,105,128,139,150,155,162,170,171,182–184,189,196 There were no trials exclusively in females, or participants of Asian, Hispanic, and/or African descent.

Reporting of participants’ ethnic background was as follows:

- Ten trials reported a mean of 85 percent of participants of European descent (range 75 to 94 percent)
- Three trials reported a mean of 3 percent of participants of Asian descent (range 2 to 4 percent)
- Five trials reported a mean of 9 percent of participants of Hispanic descent (range 1 to 22 percent)
- Four trials reported a mean of 9 percent of participants of African descent (range 5 to 15 percent)

Trial duration ranged from six to 52 weeks, with an average of 23 weeks. Although no trial totally excluded the female gender, on average 37 percent of participants were women (range, 9 to 50 percent). The average of mean ages of participants was 57 years (range of mean age 51 to 67 years). Eight trials recruited outpatients,49,104,105,128,139,155,183,196 while seven trials did not report recruitment setting. The mean Jadad score was 2.7 (range 1 to 5) and four trials had adequate allocation concealment.104,105,171,196

Of these fifteen trials, two trials were exclusively in participants requiring intensive lipid lowering treatment (i.e. participants with established vascular disease and/or diabetes mellitus and/or baseline LDL-c above 190 mg/dL).49,162

#### LDL-c Targets and Other Surrogate Markers

Comparing statin plus niacin versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants reaching ATP III LDL-c goals

The incidence of participants reaching their ATP-III targets was reported for one trial in participants not in particular need of intensive lipid lowering (Table 32).49 This trial compared a fixed dose combination of lovastatin plus extended release niacin with atorvastatin or simvastatin monotherapy. Data was available for a subgroup of participating requiring intensive lipid lowering therapy and demonstrated nonsignificant results. In addition, two balanced pairs of treatment groups for the whole trial were analyzed. Neither of the comparisons yielded any statistically significance between the two groups, but the two comparisons were not pooled because of substantial heterogeneity (I2 = 63 percent).

##### LDL-c, percentage mean change from baseline

LDL-c percent change from baseline was reported for one trial in participants requiring intensive lipid lowering using various doses of atorvastatin in combination and monotherapy arms (Table 33).162 No statistically significant difference was noted between the two groups, with a mean difference of 0.00 (95% CI −6.51, 6.51). No trial data was available that compared niacin plus a lower dose statin versus higher dose statin monotherapy in participants requiring intensive lipid lowering.

One study presented data for niacin plus a lower dose statin versus higher dose statin monotherapy in participants not in particular need for intensive lipid lowering comparing extended release niacin 2 g/day plus rosuvastatin 10 mg/day with rosuvastatin 40 mg/day monotherapy (Tables 33).155 Combination therapy had a significantly higher percent change in LDL-c, with a mean difference of 12.00 percent (95% CI 2.26, 21.74) and therefore favoring monotherapy.

In all trial populations, using various statins and doses, LDL-c percent change from baseline was reported for seven trials (Table 33; Appendix G, Figure G-53).104,105,139,155,162,182,184 Pooling of studies was not possible due to substantial heterogeneity (I2 = 85 percent), that may be explained due to the use of various statins and doses. Trials that used similar statins and doses in monotherapy and combination arms demonstrated a significant reductions in percentage LDL-c compared with trials that employed higher dose or potency of statin monotherapy showing no significant difference (Figure 50).104,105,182,184

##### HDL-c, percentage mean change from baseline

HDL-c percent change from baseline was reported for one trial in participants requiring intensive lipid lowering therapy (Table 34).162 There was a significant increase in HDL-c in the Niacin plus statin group compared with the statin monotherapy group, with a mean difference of 13.00 percent (95% CI 6.01, 20.00). No trial data was available that compared niacin plus a lower dose statin versus higher dose statin monotherapy in participants requiring intensive lipid lowering.

In all trial populations, one study presented data for niacin plus a lower dose statin versus higher dose statin monotherapy in participants not in particular need for intensive lipid lowering comparing extended release niacin 2 g/day plus rosuvastatin 10 mg/day with rosuvastatin 40 mg/day monotherapy (Tables 34).155 Combination therapy significantly increased the HDL-c percentage from baseline compared with monotherapy with a mean difference of 13.00 percent (95% CI 6.10, 19.90).

In all trial populations comparing various statins and doses in combination and monotherapy, HDL-c percent change from baseline was available for six trials (Table 34).104,105,139,155,162,182 Pooling of the studies was not possible due to substantial heterogeneity (I2 = 76 percent). Trials that used similar statins and doses of lovastatin in monotherapy and combination arms demonstrated a greater percentage increase in HDL-c from baseline with combination therapy, 104,105,182 compared to trials that used more potent statins in combination and monotherapy. With high doses of rosuvastatin in both treatment arms, no significant change was noted for this outcome.

##### Total cholesterol:HDL-c ratio, percentage mean change from baseline

No trial data was available for participants requiring intensive lipid lowering. In all trial populations, the TC:HDL-c ratio percent change from baseline was reported for one trial (Table 35).139 The TC:HDL-c ratio was significantly lower following niacin plus statin than with statin monotherapy, with a mean difference of −6.00 percent (95% CI −9.60, −2.40).

##### Measures of atherosclerosis

Carotid intima-media thickness (CIMT) was reported for only one trial, as mean change from baseline in a participant requiring intensive lipid lowering therapy (Table 36).196 Niacin plus statin combination therapy was marginally more effective than statin monotherapy in reducing the rate of increase in CIMT over 52 weeks, with a mean difference of −0.03 mm (95% CI −0.06, 0.00).

#### Harms and Treatment Adherence

Comparing statin plus ezetimibe versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants adherent to treatment

In all trial populations, one study presented data for niacin plus a lower dose statin versus higher dose statin monotherapy in participants not in particular need for intensive lipid lowering comparing extended release niacin 2 g/day plus rosuvastatin 10 mg/day with rosuvastatin 40 mg/day monotherapy.155 Treatment adherence was significantly lower with niacin plus statin than with statin monotherapy, with an odds ratio of 0.40 (95% CI 0.19, 0.84).

In all trials, using various statins and doses, treatment adherence was reported for five trials (Table 37).49,139,155,182,196 Pooling of the studies demonstrated no significant difference in the incidence between the groups treated with niacin plus statin compared with statin monotherapy, with an odds ratio of 0.79 (95% CI 0.50, 1.27). Two of the trials had long-term followup of 24 to 52 weeks duration.155,196 Pooling of the studies was not possible due to substantial heterogeneity (I2 = 59 percent).

##### Participants with at least one adverse event

In all trial populations, one study presented data for niacin plus a lower dose statin versus higher dose statin monotherapy in participants not in particular need for intensive lipid lowering comparing extended release niacin 2 g/day plus rosuvastatin 10 mg/day with rosuvastatin 40 mg/day monotherapy.155 There was no significant difference in the incidence of participants experiencing an adverse event between the combination and monotherapy arms, with an odds ratio of 1.94 (95% CI 0.79, 4.78).

In all trials, using various statins and doses, total participants with adverse events were reported for six trials (Table 37),104,105,150,155,171,182 which were not pooled due to substantial heterogeneity (I2 = 57 percent). This heterogeneity could not be explained, however, three of six trials showed significantly more participants experiencing adverse events with statin-niacin combination when compared with monotherapy.

##### Participants withdrawing due to adverse events

In all trials using various statins and doses, withdrawals due to adverse events was reported for ten trials (Table 37; Appendix G, Figure G-56).49,104,105,128,150,170,171,182,189,196 Pooling of the studies demonstrated a significantly higher incidence of withdrawals in the combination group with an odds ratio of 2.38 (95% CI 1.63, 3.47). No trial data was available that compared niacin plus a lower dose statin versus higher dose statin monotherapy.

##### Participants with AST and/or ALT above three times the upper limit of normal, and/or hepatitis

In all trial populations, one study presented data for niacin plus a lower dose statin versus higher dose statin monotherapy in participants not in particular need for intensive lipid lowering comparing extended release niacin 2 g/day plus rosuvastatin 10 mg/day with rosuvastatin 40 mg/day monotherapy.155 There were no instances of elevated serum AST and/or ALT above 3 times the upper limit of normal and/or hepatitis recorded.

In all trials, using various statins and doses, elevated serum AST and/or ALT above 3 times the upper limit of normal and/or hepatitis was reported for ten trials,49,104,128,150,155,162,170,171,182,196 five of which reported events and therefore provided analyzable data (Table 37).104,128,162,170,182 Pooling of the studies demonstrated no significant difference in the incidence between the two groups with an odds ratio of 1.39 (95% CI 0.36, 5.36), based upon 12 events in 1,942 participants.

##### Participants with myalgia

In all trials, using various statins and doses, incidence of myalgia was reported for three trials.49,105,128 Pooling of the studies demonstrated a nonsignificant difference in the incidence of myalgia in both groups with an odds ratio of 0.45 (95% CI 0.19, 1.07), based upon 22 events in 665 participants. No trial data was available that compared niacin plus a lower dose statin versus higher dose statin monotherapy.

##### Participants with CPK above 10 times the upper limit of normal

In all trial populations, one study presented data for niacin plus a lower dose statin versus higher dose statin monotherapy in participants not in particular need for intensive lipid lowering comparing extended release niacin 2 g/day plus rosuvastatin 10 mg/day with rosuvastatin 40 mg/day monotherapy.155 There were no instances of CPK above 10 times the upper limit of normal (Table 37).

In all trials, using various statins and doses, the incidence of CPK above 10 times the upper limit of normal was reported in nine trials, with one event identified for 1690 participants for the trials‘ respective followup durations with a nonsignificant odds ratio of 16.70 (95% CI 0.28, 1002.74) (Table 37).49,104,105,139,155,162,170,171,182

##### Participants with rhabdomyolysis

In all trial populations, using various statins and doses, rhabdomyolysis was reported not to have occurred in four trials in 944 participants (Table 37).104,105,150,171

### Key Question 3: Compared with higher-dose statins, and to one another, do combination regimens differ in benefits and harms within subgroups of patients?

Table 30

Availability of evidence addressing niacin key question 3 for statin plus niacin versus statin monotherapy comparison

[table image]

Abbreviations: ATP III = the third Adult Treatment Panel III Adult Treatment Panel of the National Cholesterol Education Program, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, TC = total cholesterol

#### Clinical Outcomes

Comparing statin plus niacin versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### All-cause mortality

###### Participants with established vascular disease

Incidence of all cause mortality was reported for one trial, for the subgroup of participants with vascular disease (Table 31).196 There was no statistically significant difference between the two treatment groups, with an odds ratio of 1.84 (95% CI 0.16, 20.76) for both subgroups.

##### Vascular death

###### Participants with established vascular disease

The incidence of vascular death was reported for one trial, for participants with established vascular disease (Table 31).197 No events were recorded.

#### LDL-c Targets and Other Surrogate Markers

Comparing statin plus niacin versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants reaching ATP III LDL-c goals

###### Participants with established vascular disease

The surrogate outcome incidence of participants reaching their ATP-III targets was reported for one trial with established vascular disease (Table 33).49 No statistically significant difference was noted between the two groups (OR 1.51, 95% CI 0.56, 4.08).

##### LDL-c, percentage mean change from baseline

###### Participants with established vascular disease

The surrogate outcome LDL-c percent change from baseline for participants with established vascular disease was reported for one trial (Table 33).162 No statistically significant difference was noted between the two groups (MD 0.00, 95% CI -6.51, 6.51).

##### HDL-c, percentage mean change from baseline

###### Participants with established vascular disease

HDL-c percent change from baseline was reported for one trial (Table 34).162 There a significant increase in HDL-c in the combination group compared with monotherapy (MD 13.00 percent, 95% CI 6.01, 20.00).

#### Strength of Evidence

The strength of the available evidence was assessed as GRADE (Grading of Recommendations Assessment, Development and Evaluation)225 for the key outcomes all-cause mortality, vascular death, serious adverse events and achieving ATP-III target LDL-c. Results generated using the GRADEpro software are presented in Tables H-17 to H-20 (Appendix H) can be summarized as follow:

1. Based on a single study in participants requiring intensive lipid lowering therapy, GRADE was “very low” for all cause mortality, vascular death and participants reaching ATP III LDL-c goals for the combination of any dose statin plus niacin compared to any dose statin (Appendix H, Table H-17).
2. Based on a single study in participants with established vascular disease, GRADE was “very low” for all cause mortality, vascular death and participants reaching ATP III LDL-c goals for the combination of any dose statin plus niacin compared to any dose statin (Appendix H, Table H-18).
3. Based on studies in participants followed up for more than 24 weeks and comparing the combination of any dose statin plus niacin to any dose statin, GRADE was “very low” for all cause mortality (4 trials), vascular death (1 trial) and serious adverse events (3 trials) (Appendix H, Table H-19).
4. Based on studies in participants regardless of baseline risk and comparing the combination of any dose statin plus niacin to any dose statin, GRADE was “very low” for all cause mortality (6 trials), vascular death (2 trials), serious adverse events (5 trials) and participants reaching ATP III LDL-c goals (1 trial) (Appendix H, Table H-20).

### Evidence Summary Tables: Statin Plus Niacin Combination Therapy Versus Statin Monotherapy

Table 31

Quantitative syntheses of longer term outcomes (clinical, serious adverse events and cancer) for niacin plus a statin therapy compared with statin monotherapy

| Number of trials reporting outcome | Number of participants in relevant treatment groups | Number of Events | Odds ratio | Lower CI | Upper CI
All-cause mortality
Participants requiring intensive lipid lowering therapy – All trials196
Participants requiring intensive lipid lowering therapy – All trials 24 weeks or more followup196 | 1 | 149 | 3 | 1.84 | 0.16 | 20.76
Participants requiring intensive lipid lowering therapy – Trials with adequate allocation concealment196
Participants with vascular disease196
All trials104,105,150,170,171,196 | 6 | 1213 | 5 | 1.08 | 0.17 | 6.72
All trials 24 weeks or more followup105,150,171,196 | 4 | 960 | 5 | 1.08 | 0.17 | 6.72
Trials with adequate allocation concealment104,105,171,196 | 3 | 792 | 5 | 1.08 | 0.17 | 6.72
Vascular death
Participants requiring intensive lipid lowering197 | 1 | 54 | 0 | - | - | -
Participants with vascular disease197
All trials128,197 | 2 | 229 | 2 | 0.53 | 0.03 | 8.64
All trials 24 weeks or more followup128 | 1 | 175 | 2 | 0.53 | 0.03 | 8.64
Fatal myocardial infarction
All trials105,197 | 2 | 229 | 1 | 4.64 | 0.08 | 283.78
All trials 24 weeks or more followup105 | 1 | 175 | 1 | 4.64 | 0.08 | 283.78
Participants requiring intensive lipid lowering therapy197 | 1 | 54 | 0 | - | - | -
Any unspecified stroke
All trials196
All trials 24 weeks or more followup196 | 1 | 149 | 1 | 0.12 | 0.00 | 6.21
Participants requiring intensive lipid lowering therapy196
Acute coronary syndrome
All trials196 | 1 | 149 | 4 | 0.91 | 0.12 | 6.62
Percutaneous coronary intervention
All trials196
Participants requiring intensive lipid lowering therapy196 | 1 | 149 | 5 | 3.78 | 0.41 | 34.68
All trials 24 weeks or more followup196
Serious adverse events
All trials104,105,150,170,171 | 5 | 1064 | 16 | 1.29 | 0.44 | 3.80
All trials 24 weeks or more followup105,150,171 | 3 | 811 | 9 | 1.00 | 0.26 | 3.86
Cancer
All trials105 | 1 | 175 | 2 | 0.10 | 0.00 | 2.20

Abbreviations: CI = 95% confidence interval

Table 32

Quantitative syntheses of the incidence of participants achieving ATP-III LDL-c targets, for niacin plus a statin therapy compared with statin monotherapy

| Number of trials | Dose Niacin (mg/day) | Number of participants in relevant treatment groups | Number of participants with events | Odds ratio | Lower CI | Upper CI
Relative probability of attaining ATPIII target
Participants requiring intensive lipid lowering therapy49 | 1 | 2000 | 66 | 40 | 1.51 | 0.56 | 4.08
Participants with vascular disease49
All trials49 | 1 | 2000 | 222 | 166 | - | - | -

Abbreviations: ATP III = the third Adult Treatment Panel III Adult Treatment Panel of the National Cholesterol Education Program, CI = 95% confidence interval, LDL-c = low density lipoprotein cholesterol

Table 33

Quantitative syntheses of LDL-c data, for niacin plus a statin combination therapy compared with statin monotherapy

| Number of trials | Number of participants in relevant treatment groups | Point Estimate | Lower CI | Upper CI
Difference in mean percentage change from baseline (%)
Participants requiring intensive lipid lowering therapy162 | 1 | 83 | 0.00 | −6.51 | 6.51
Participants with vascular disease162
All trials104,105,139,155,162,182,184 | 7 | 673 | - | - | -
Rosuvastatin - Lower dose statin in combination versus higher dose monotherapy155 | 1 | 124 | 12.00 | 2.26 | 21.74

Abbreviations: CI = 95% confidence interval, LDL-c = low density lipoprotein cholesterol

Table 34

Quantitative syntheses of HDL-c data, for niacin plus a statin combination therapy compared with statin monotherapy

Population | Number of trials | Number of participants in relevant treatment groups | Point Estimate | Lower CI | Upper CI
Difference in mean percentage change from baseline
Participants requiring intensive lipid lowering therapy162 | 1 | 83 | 13.00 | 6.01 | 20.00
Participants with vascular disease162
All trials104,105,139,155,162,182 | 6 | 732 | - | - | -
Rosuvastatin Lower dose statin in combination compared with higher dose monotherapy155 | 1 | 67 | 13.00 | 6.10 | 19.90

Abbreviations: CI = 95% confidence interval, HDL-c = high density lipoprotein cholesterol

Table 35

Quantitative syntheses of total cholesterol:HDL-c ratios, for niacin plus a statin combination therapy compared with statin monotherapy

Population | Number of trials | Number of participants in relevant treatment groups | Max dose niacin (mg/d) | Point estimate | Lower CI | Upper CI
Difference in mean percentage change in TC: HDL-c ratio (%)
All trials139 | 1 | 198 | 2000 | −6.00 | −9.60 | −2.40

Abbreviations: CI = 95% confidence interval, HDL-c = high density lipoprotein cholesterol, TC = total cholesterol

Table 36

Quantitative synthesis of CIMT data, for niacin plus a statin combination therapy compared with statin monotherapy

| Number of trials | Number of participants in relevant treatment groups | Max dose niacin (mg/d) | Point estimate | Lower CI | Upper CI
Difference in mean CIMT
All trials196
Participants requiring intensive lipid lowering therapy196 | 1 | 149 | 1000 | −0.03 | −0.06 | 0.003

Abbreviations: CI = 95% confidence interval, CIMT = carotid intima-medial thickness

Table 37

Quantitative syntheses of short term harms and adherence to treatment, for niacin plus a statin combination therapy compared with statin monotherapy

Population | Number of trials | Niacin Dose (mg/d) | Number of participants in relevant treatment groups | Number of events | Odds ratio | Lower CI | Upper CI
Relative probability of participants adhering to treatment
All trials49,139,155,182,196 | 5 | 1000 – 2500 | 1011 | 851 | 0.79 | 0.50 | 1.27
Trials 24-weeks or longer followup155,196 | 2 | 1000 –2000 | 365 | 251 | - | - | -
Rosuvastatin
Lower dose statin in combination versus higher dose monotherapy155 | 1 | 2000 | 126 | 67 | 0.40 | 0.19 | 0.84
Relative probability of participants experiencing an adverse event
All trials104,105,150,155,171,182 | 6 | 2000 – 2500 | 1275 | 681 | - | - | -
Trials 24 weeks or longer followup105,150,155,171 | 4 | 1000 – 2000 | 1009 | 499 | - | - | -
Rosuvastatin
Lower dose statin in combination versus higher dose monotherapy155 | 1 | 2000 | 124 | 100 | 1.94 | 0.79 | 4.78
Relative probability of participants withdrawing from treatment due to an adverse event
All trials49,104,105,128,150,170,171,182,189,196 | 10 | 1000 – 3000 | 1900 | 223 | 2.38 | 1.63 | 3.47
Relative probability of participants experiencing rhabdomyolysis
All trials104,105,150,171 | 4 | 2000 –2500 | 944 | 0 | - | - | -
Relative probability of participants experiencing elevated serum AST and/or ALT greater than 3 times the upper limit of normal, and/or hepatitis
All trials49,104,128,150,155,162,170,171,182,196 | 10 | 1000 – 2500 | 1942 | 12 | 1.39 | 0.36 | 5.36
Rosuvastatin
Lower dose statin in combination versus higher dose monotherapy155 | 1 | 2000 | 126 | 0 | - | - | -
Relative probability of participants experiencing myalgia
All trials49,105,128 | 3 | 2000 | 665 | 22 | 0.45 | 0.19 | 1.07
Relative probability of participants experiencing CPK greater than 10 times the upper limit of normal
All trials49,49,104,105,139,155,170,182 | 10 | 2000 – 2500 | 1690 | 1 | 16.70 | 0.28 | 1002.74
Rosuvastatin
Lower dose statin in combination versus higher dose monotherapy155 | 1 | 2000 | 126 | 0 | - | - | -

Abbreviations: ALT = alanine transaminase, AST = aspartate transaminase, CI = 95% confidence interval, CPK = creatinine phosphokinase

## Statin Plus Bile Acid Sequestrant Combination Therapy Versus Statin Monotherapy

### Overview of Included Studies

A total of 17 RCTs evaluated the relative efficacy and/or harm of the combination of statin plus bile acid sequestrant (BAS) (cholestyramine 1.6 to 24 g/day, colesevelam 2.3 to 3.8 g/day, colestipol 1.65 to 20 g/day) therapy compared with statin monotherapy, in a total of 2,930 participants (Table 3; Appendix F, Table F-24 to F-28). In addition, two non-randomized studies addressed this comparison (Table 4).88,89 Two trials included companion reports (Table 6); one in the published literature, 198 and one a Federal Drug Agency report of an extension of treatment and followup for a longer period of time.172 The longest available data for any given trial were analyzed. One companion report was considered for trial referencing.212

Twelve trials were conducted in multiple centers 52,122,133,137,164,172,174,185,186,190,191,198, and three in single centers.136,163,173 Information regarding site was not reported for two trials.108,135 Fifteen of the 17 trials were partially or completely sponsored by the pharmaceutical industry,52,108,122,133,135–137,172,174,185,186,190,191,198 while funding was not disclosed for two trials.163,164 Total Jadad scores ranged from one to five with an average score of 2. An appropriate method of randomization was reported for three trials,172,173,190 and appropriate methods of double blinding were reported for four trials.133,172,173,185 Allocation concealment was deemed adequate for three trials 122,172,173 and the results of two trials were based on intention-to-treat analyses.133,135

Most trials (12) were carried out in North America,52,108,122,133,135,136,163,172,185,186,191 with three trials in Europe137,173,190 and two trials in Australia.174,198

Reporting of participants' ethnicity was provided in five trials as follow

- European descent (89 to 96 percent)52,122,172,185,191
- Hispanic descent (1.3 to 1.5 percent)172,185
- African descent (3 to 8 percent)52,122,172,185
- Asian descent (3 percent)185

Neither power analyses regarding the primary outcome measures nor adjudication of outcomes were reported. Also, except for two trials,52,191 active clinical adverse event data collection was either not reported or unclear.

### Key Question 1: For patients who require intensive lipid-modifying therapy, what are the comparative long-term benefits, and rates of serious adverse events of coadministration of different lipid-modifying agents (i.e. a statin plus another lipid-modifying agent) compared with higher dose statin monotherapy?

#### Study Design and Population Characteristics

A total of four parallel group RCTs including 511 participants compared statin plus BAS combinations and statin monotherapy, and reported one or more clinical outcomes or serious adverse events (Table 41; Appendix F, Table F-24).52,172,185,198 Three trials provided information on participants' ethnic descent.52,172,185 In included arms of those trials, 89 to 95 percent of participants were of European descent, 3 to 7 percent of African descent, 1.5 percent of Hispanic descent and 2.6 percent of Asian descent. No trial was conducted exclusively in one gender. On average, 51 percent of participants were female (range 43 to 60 percent). The average of mean ages of participants was 54 years (range 49 to 59 years). Two trials recruited outpatients,172,198 while two trials did not report recruitment setting.52,185 Mean Jadad score was 3 (range 1 to 5) and one trial had adequate allocation concealment.172 No trials were exclusively in participants requiring intensive lipid lowering therapy.

The participants in these four trials were relatively homogenous, as none of the trials were performed in high risk participants, and none reported prior statin exposure. Most trials excluded participants with triglycerides above 300 to 600 mg/dL, patients with recent or unstable vascular disease, uncontrolled diabetes mellitus and hypertension, liver and muscle disease or high ALT, AST and/or CPK, and/or impaired renal function. No trial employed a statin plus BAS combined pill.

Table 38

Evidence addressing key question 1 for statin plus BAS versus statin monotherapy comparison

Outcomes | Extractable data availability | Key points of evidence synthesis
All-cause mortality | Yes | Three trials compared BAS-statin combination therapy with the same statin and same dose monotherapy. A significant difference was not observed in participants with mixed risk factors. These trials reported 2 deaths in 373 evaluable participants.
Vascular death | No
Fatal myocardial infarction (MI) | Yes | One trial compared BAS-statin combination with the same statin and same dose monotherapy. A significant difference was not observed in participants with mixed risk factors. This trial reported 1 fatal MI in 150 evaluable participants.
Non-fatal MI | No
Any or unspecified MI | No
Acute coronary syndrome (ACS) (encompassing unstable angina or acute MI) | No
Any cerebrovascular event | No
Hemorrhagic stroke | No
Ischemic stroke | No
Any or unspecified stroke | No
Transient ischemic attack (TIA) | No
Carotid endarterectomy (CEA) | No
Percutaneous coronary interventional procedure (PCI) | No
Coronary artery bypass graft procedure (CABG) | No
Any or unspecified revascularization procedure | No
Serious adverse events | Yes | Two trials compared BAS-statin combination therapy with the same statin and same dose monotherapy. A significant difference was not observed in participants with mixed risk factors. These trials reported 7 SAEs in 278 evaluable participants.
Cancer | No

Abbreviations: ACS = acute coronary syndrome, CABG = coronary artery bypass graft, CEA = carotid endarterectomy, MI = myocardial infarction, PCI = percutaneous coronary intervention, SAE = serious adverse event

#### Long-Term Efficacy, Serious Adverse Events, and Cancer

Comparing statin plus BAS versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### All-cause mortality

Three trials in 373 evaluable participants reported two deaths during a follow up of four to 24 weeks duration (Table 41).52,172,185 Only one of these trials, in 150 participants, was based on treatment and follow up of 24 weeks.52 This study compared fluvastatin 10–20 mg/day and cholestyramine 16 g/day plus fluvastatin 10 to 20 mg/day, and reported one death.52 Across these three trials of four to 24 weeks duration, two trials with 151 evaluable participants and a total of two deaths could be meta-analyzed (Appendix G, Figure G-57).52,172 A nonsignificant odds ratio of 1.07 (95% CI 0.11, 10.51) was observed (Table 41). A report of one trial with adequate allocation concealment had a nonsignificant estimable odds ratio of 3.25 (95% CI 0.13, 82.24) (Appendix F, Table F-24).172 No report permitted comparison of lower dose statin plus BAS with higher dose statin monotherapy, and none of the trials was performed specifically in participants requiring intensive lipid lowering therapy.

##### Fatal myocardial infarction

One trial in 150 evaluable participants compared fluvastatin (10–20 mg/day) and cholestyramine (16 g/day) with fluvastatin (10–20 mg/day), and reported one fatal myocardial infarction on monotherapy. A nonsignificant odds ratio of 0.35 (95% CI 0.01, 8.91) was observed (Table 41). 52

##### Serious adverse events

Seven participants experienced serious adverse events during two trials on 278 evaluable participants, during a followup of six to 30 weeks (Table 41).172,198 Simons et al compared simvastatin (40 mg/day) plus cholestyramine (4 g/day) with atorvastatin (80 mg/day) monotherapy in 136 participants, with six serious adverse events during a followup of 30 weeks.198 Knapp et al compared simvastatin (10 to 20 mg/day) plus colesevelam (2.3 to 3.8 g/day) with simvastatin (10 to 20 mg/day) monotherapy in 142 participants, with one serious adverse event during a six week trial (Appendix F, Table F-24).172 The pooled nonsignificant odds ratio was 0.39 (95% CI 0.06, 2.36) (Appendix G, Figure G58).

##### Non-RCT evidence

Two non-randomized controlled trials compared statin plus BAS therapy with statin monotherapy (Table 42). Ojala et al88 added colestipol (dose range from 5 to 20 g/day) to treatment of patients with primary hypercholesterolemia, some of whom had CHD. LDL-c was above 120 mg/dL in CHD patients or above 140 mg/dL for those without CHD, despite the use of lovastatin 80 mg/day. The only reported outcome of interest was the absence of serious adverse events in either treatment group during the three year follow up.88 Mol et al compared simvastatin 40mg/day plus cholestyramine 4 g/day or colestipol 5g/day, with simvastatin 40 mg/day in 26 patients with severe familial hypercholesterolemia, for two years.89 In the combination group, one participant experienced a myocardial infarction and one experienced unstable angina, but there were no cases of coronary arterial bypass graft.89 No other outcome of interest was reported (Table 42).

### Key Question 2: Do these regimens differ in reaching LDL-targets (or other surrogate markers), short-term side effects, tolerability, and/or adherence?

#### Study Design and Population Characteristics

Records of seventeen trials comparing a statin plus BAS combination with statin monotherapy reported one or more surrogate efficacy or harm outcomes, other than serious adverse events and cancer (Table 39; Appendix F, Table F-25 to F-28).52,108,122,133,135–137,163,164,172–174,185,186,190,191,198 These trials included 2,930 randomized participants. No trials were of crossover design. Six records provided information on participants' descent,52,122,164,172,185,191 with reports of 87 to 96 percent of participants of European descent, 3 to 8 percent of African descent, 1.5 percent of Hispanic descent and 2.6 percent of Asian descent. Trial duration ranged from four to 192 weeks with an average of 32 weeks. One trial was conducted exclusively in males.108 In the remaining 16 trials, on average 38 percent of participants were females (range, 5 to 60 percent ). The average of mean ages of participants was 54 years (range of mean age, 45 to 62 years). Five trials recruited outpatients,133,172,190,191,198 while 12 trials did not report recruitment setting. Mean Jadad score was 2 (range 1 to 5) and four trials had adequate allocation concealment .122,172,173,190 Five of these trials included 426 participants requiring intensive lipid lowering treatment and/or participants with baseline LDL-c above 190 mg/dL.108,122,163,174,198

Table 39

Evidence addressing key question 2 for statin plus BAS versus statin monotherapy comparison

Relevant outcomes | Extractable data availability | Key points of evidence synthesis
Participants attaining ATP III LDL-c targets | Yes | One trial comparing lower dose statin in combination with higher dose monotherapy in participants with history of cardiovascular diseases favored combination therapy.
LDL-c | Yes | Compared with same statin monotherapy (one trial with higher statin dose) in participants with heterogeneous risk factors, nine of 11 trials favored BAS-statin combination, but results could not be pooled.
HDL-c | Yes | Nine trials compared combination therapy with the same statin monotherapy (one trial with higher statin dose) in participants with heterogeneous risk factors. A significant difference was not observed.
TC:HDL ratio | No
Carotid artery | No
Coronary artery | No
Treatment Adherence | Yes | Five trials compared combination therapy with the same statin monotherapy (two trials with higher statin dose monotherapy) in participants with heterogeneous risk factors. All trials favored monotherapy, but results could not be pooled.
All participants with adverse events | Yes | Four trials compared combination therapy with the same statin monotherapy (one trial with higher statin dose monotherapy) in participants with heterogeneous risk factors. All trials favored monotherapy, but results could not be pooled.
Withdrawal due to adverse events | Yes | Eight trials compared combination therapy with the same statin monotherapy (four with higher statin dose monotherapy) in participants with heterogeneous risk factors, with 31 withdrawals due to AEs in 966 evaluable participants. No significant difference was observed.
Elevated AST and/or ALT > 3 times ULN and/or hepatitis | Yes | Two 4 to 30 week trials in 212 evaluable participants reported no events.
Myalgia | Yes | Four trials comparing combination therapy with the same statin monotherapy (one with higher statin dose) in participants with heterogeneous risk factors, reported 11 episodes of myalgia in 343 evaluable participants. No significant difference was observed.
CPK > 10 times ULN | Yes | Two 6 to 30 week trials in 283 evaluable participants reported no events.
Rhabdomyolysis (investigator defined) | No

Abbreviations: ALT = alanine transferase, AST = aspartate transferase, ATP III = Third Adult Treatment Panel of the National Cholesterol Education Program, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, TC = total cholesterol

Three trials included only participants with familial combined hypercholesterolemia,136,163,164 three included participants all with LDL-c above 190mg/dL,122,163,198 two reported past history of coronary artery diseases in most or all participants,108,174 and one reported that all participants had prior statin exposure.122 The other seven trials were relatively homogenous regarding participants‘ characteristics. Most trials excluded participants with TG above 300 to 600 mg/dL, recent or unstable vascular disease, uncontrolled diabetes mellitus or hypertension, liver and muscle disease, high ALT, AST and CPK, or impaired renal function. No trial employed a BAS plus statin combined pill.

#### LDL-c Targets and Other Surrogate Markers

Comparing statin plus BAS versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants reaching ATP III LDL-c goals

One record of a 12 week trial on 59 evaluable participants reported attainment of ATP III LDL-c targets (Table 43).108 This trial compared pravastatin 20 mg/day plus cholestyramine 10 g/day with pravastatin 40 mg/day in 59 male North American participants. All had moderate hypercholesterolemia, history of coronary artery diseases and prior use of statins. Eighteen participants reached ATP III LDL-c target levels, yielding a nonsignificant odds ratio of 4.51 (1.34, 15.14) favoring combination therapy (Table 43; Appendix F, Table F-25).108

##### LDL-c, percentage mean change from baseline

A total of 11 trials provided data on 15 pairs of analyzable arms on 1010 evaluable participants.52,122,133,163,164,172–174,185,191,198 Followup duration ranged from four to 40 weeks, with the majority of trials less than 24 weeks in duration. Across trials, participant characteristics were relatively heterogeneous, with four trials including participants with moderate to severe familial hypercholesterolemia requiring intensive lipid lowering therapy,122,163,174,198 and/or LDL-c above190 mg/dL at baseline.122,163,198

Meta-analysis was not possible due to substantial statistical heterogeneity (I2 = 88 percent). However, most trials demonstrated significant percentage reductions from baseline in favor of statin plus BAS combination therapy compared with statin monotherapy, ranging from 4 to 16 percent (Table 44; Appendix G, Figure G-59). In contrast, two trials showed a difference in means favoring monotherapy. One 30 week trial in 136 participants comparing simvastatin 40 mg/day plus cholestyramine 4 g/day, with atorvastatin 80 mg/day monotherapy in participants with no prior exposure to statins, showed a significant difference in means of 11 percent (95% CI 6.45, 15.55) in favor of monotherapy.198 Another 32 week trial in 37 participants, comparing mixed statins plus colestipol 20 g/day with atorvastatin 80 mg/day monotherapy in participants heterogeneous familial and polygenic hypercholesterolemia, showed a nonsignificant difference in means of 5.43 percent (95% CI -1.84, 12.7) in favor of monotherapy.163 When the analyses were rerun after removing these two outliers a significant percentage reductions from baseline in favor of statin plus BAS combination of -10.6 percent (95% CI -12.56, -8.65) was demonstrated, without significant heterogeneity (I2 = 17.7 percent). There was no significant lateral asymmetry on the funnel plot, with an Egger‘s regression intercept of −1.7, and two tailed p-value > 0.647.

Four trials contributed efficacy data comparing statin plus BAS therapy with statin monotherapy, regardless of statin dose, in those who require intensive lipid lowering therapy (i.e. participants with baseline LDL-c above 190 mg/dL, or history of coronary artery disease).122,163,174,198 Persistent statistical heterogeneity prevented meta-analysis (I2 = 89 percent). Results of individual trials were inconsistent, with one trial showing a mean percentage change of -10 percent in favor of combination (95% CI -19.92, -0.28)174, one trial showing significant results favoring monotherapy (MD 11; 95% CI 6.45, 15.55)198 and two trials yielding nonsignificant mean differences in percentage change from baseline LDL-c ranging from -4.1 to 5.4 percent (Table 44; Appendix G, Figure G-60).122,163 Hunninghake et al provided data comparing lower dose atorvastatin 10 mg/day plus colesevalam 3.8 g/day with higher dose atorvastatin 80 mg/day monotherapy.133 This study investigated 38 participants without any particular risk factor and reported a percentage mean difference of 5.00 percent (95% CI -3.34, 13.34) (Table 44).

##### HDL-c, percentage mean change from baseline

A total of nine trials provided 10 pairs of meta-analyzable data on 911 evaluable participants.52,122,163,164,173,174,185,191,198 Followup duration ranged from four to 40 weeks, and five trials were more than 24 weeks in length. Across trials, participants presented with moderate to severe familial hypercholesterolemia and/or LDL-c above190 mg/dL at baseline.122,163,174,198 Pooled results yielded an estimable mean percentage difference of 0.33 percent (95% CI -1.86, 2.52) and no significant heterogeneity (I2 = 29 percent) (Table 45). Asymmetry was not evident on the funnel plot.

Four trials contributed efficacy data comparing statin plus BAS with statin monotherapy, for all statin doses, in those requiring intensive lipid lowering therapy.122,163,174,198 Pooled results showed an estimable mean percentage difference of 2.25 percent (95% CI -0.56 mg/dL, 5.06 mg/dL) and no significant heterogeneity (I2 = 3 percent) (Table 45; Appendix F, Table F-27). None of the trials provided evaluable data comparing combination therapy using lower dose statin with higher dose statin monotherapy.

#### Harms and Treatment Adherence

Comparing statin plus BAS versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants adherent to treatment

Five trials of four to 96 weeks duration provided analyzable data in 1420 evaluable participants.122,133,137,164,190 Data could not be pooled because of significant heterogeneity (I2 = 53 percent) (Table 46; Appendix F, Table F-28). Asymmetry was not evident on the funnel plot (Appendix G, Figure G-62). One long-term trial (96 weeks) compared pravastatin 20 mg/day plus cholestyramine 8 g/day with pravastatin 20 to 40 mg/day monotherapy, in 1073 evaluable participants, and yielded a significant odds ratio of 0.41 (95% CI 0.26, 0.7) in favor of monotherapy.190 Four trials with less than 24 months followup yielded odds ratios ranging from 0.1 to 0.97.^122,133,137,164^ Potential factors contributing to the heterogeneity among these studies included:

- One study was conducted in participants requiring intensive lipid lowering therapy because of baseline LDL-c levels above 190 mg/dL.122 Participants in the remaining four studies presented with moderate hypercholesterolemia.
- Four studies were sponsored by the pharmaceutical industry, 122,133,137,190and this information was not reported in one study.164
- All trials employed a similar statin in combination and monotherapy arms. Two trials compared lower dose statin plus BAS with higher dose statin monotherapy,133,137 one four to 12 week trial compared simvastatin 20 mg/day plus colestipol 5 to 10 g/day with higher dose simvastatin 40 mg/day monotherapy in 81 evaluable healthy participants, and yielded a nonsignificant odds ratio of 0.33 (95% CI 0.09, 1.27).137 A second trial compared atorvastatin 10 mg/day plus colesevelam 3.8 g/day with higher dose atorvastatin 80 mg/day monotherapy in 39 evaluable participants, and showed a nonsignificant odds ratio of 0.94 (95% CI 0.12, 7.48) (Table 46).133
- A procedure to guarantee adequate allocation concealment was reported in only two of the five studies.122,190

##### Participants with at least one adverse event

Four 4 to 24 week trials provided six pairs of analyzable arms including 522 evaluable participants, reporting 301 adverse events.52,122,137,172 One long-term trial (24 weeks) compared in its four arms fluvastatin 10 and 20 mg/day plus cholestyramine 8 to 16 g/day, with fluvastatin 10 and 20 mg/day monotherapy in 150 evaluable participants, and showed a pooled significant odds ratio of 5.14 (2.39, 11.07) in favor of monotherapy.52 (Table 46). Asymmetry was not evident on the funnel plot (Appendix G, Figure G-63). It is worth noting that doses of BAS varied among trials. In particular, cholestyramine was employed in combination with statins in doses varying from 1.6 g/day122 to 16 g/day.52 Only one four to12 week trial compared simvastatin 20 mg/day plus colestipol 5 to10 g/day with higher dose simvastatin 40 mg/day monotherapy, in 83 evaluable healthy participants, and yielded a nonsignificant odds ratio of 1.19 (95% CI 0.47, 3.02) (Table 46).137

##### Participants withdrawing due to adverse event

Eight trials of four to 24 week duration provided nine pairs of analyzable arms in 966 evaluable participants, with 31 withdrawals due to adverse events.52,122,133,164,172,185,191,198 Pooled results showed a nonsignificant odds ratio of 1.80 (95% CI 0.68, 4.76) and no significant heterogeneity (I2 = 19 percent) (Table 46; Appendix F, Table F-28). Asymmetry was not evident on the funnel plot (Appendix G, Figure G-64). Doses of BAS varied widely among trials. Cholestyramine was administered in four trials in doses from 1.6 to 24 g/day,52,122,191,198 colesevalam was administered in three trials in doses from 2.3 to 3.8 g/day,133,172,185 and colestipol was administered in one trial at 1.65 g/day.164

One 4 week trial compared atorvastatin 10 mg/day plus colesevalam 3.8 g/day with atorvastatin 80 mg/day monotherapy in 39 evaluable participants. There were two withdrawals due to adverse events, with a nonsignificant odds ratio of 1.06 (95% CI 0.06, 18.17)137 (Table 46).

##### Participants with AST and/or ALT above 3 times the upper limit of normal, and/or hepatitis

Two 4- to 30-week trials in 212 evaluable participants reported no cases of elevated AST/ALT above three times the upper limit of normal (Table 46; Appendix F, Table F-28).185,198

##### Participants with myalgia

Four 4 to 12 week trials reported 11 cases of myalgia among 343 evaluable participants (Table 46; Appendix F, Table F-28).108,122,173,185 A nonsignificant odds ratio of 0.43 (95% CI 0.12, 1.54), without evidence of significant heterogeneity (I2 = 0 percent) was observed. No trials with estimable data enabled comparison of lower dose statin plus BAS with a higher dose of the same statin monotherapy.

##### Participants with CPK above 10 times the upper limit of normal

Two 6- to 30-week trials in 283 evaluable participants reported no cases of elevated CPK above 10 times the upper limit (Table 46; Appendix F, Table F-28).122,198

### Key Question 3: Compared with higher-dose statins, and to one another, do combination regimens differ in benefits and harms within subgroups of patients?

Table 40

Availability of evidence addressing key question 3 for statin plus BAS versus statin monotherapy comparison

[table image]

Abbreviations: HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, TC = total cholesterol, TG = triglycerides

#### LDL-c Targets and Other Surrogate Markers

Comparing statin plus BAS versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants reaching ATP III LDL-c goals

###### Participants with established vascular diseases

A single 12-week trial in 59 evaluable participants reported attainment of ATP III LDL-c targets (Table 43).108 This trial compared pravastatin (20 mg/day) and cholestyramine (10 g/day) with pravastatin (40 mg/day) in 59 male North American participants, all with moderate hypercholesterolemia, a history of coronary artery disease and prior use of statins. Eighteen participants reached ATP III LDL-c target levels, yielding a significant odds ratio of 4.51 (1.34, 15.14) favoring combination therapy (Table 43; Appendix F, Table F-25).108 DL-c and HDL-c, percentage mean change from baseline.

##### LDL-c and HDL-c, percentage mean change from baseline

###### Participants with baseline LDL-c above 190 mg/dL

Three trials contributed efficacy data for statin plus BAS combination therapy in comparison with statin monotherapy, for any statin dose, in participants with baseline LDL-c above 190 mg/dL.122,163,198 Statistical heterogeneity precluded meta-analysis (I-squared = 78 percent). All trials showed nonsignificant mean differences in percentage change from baseline in LDL-c (Appendix G, Figure G-61). One six week trial in 144 evaluable participants employing identical high dose rosuvastatin in combination and monotherapy had a mean percentage reduction of -4.1 percent (95% CI, -9.1, 0.9).122 One 48 week trial in 37 evaluable participants compared 40 mg/day of atorvastatin or simvastatin plus 20 g/day of colestipol with 80 mg/day of atorvastatin monotherapy and had a mean percentage reduction of 5.4 percent (95% CI -1.84, 12.67).163 Finally, a 30 week trial in 136 evaluable participants compared simvastatin 40 mg/day plus cholestyramine 4 g/day with atorvastatin 80 mg/day monotherapy, and had a mean percentage reduction of 11 percent favoring monotherapy (95% CI 6.45, 15.55).198

###### HDL-c, percentage mean change from baseline in participants with baseline LDL-c above 190 mg/dL

The same three trials described above for percentage changes in LDL-c also provided data on mean percentage change in HDL-c.122,163,198 Pooled results showed an estimable mean percentage difference of 2.37 percent (95% CI -1.18, 5.93) and no significant heterogeneity (I2 = 2 percent)(Table 45).

#### Strength of Evidence

The strength of the available evidence was assessed as GRADE (Grading of Recommendations Assessment, Development and Evaluation)225 for the key outcomes all-cause mortality, vascular death, serious adverse events and achieving ATP-III target LDL-c. Results generated using the GRADEpro software are presented in Tables H-21 to H-23 (Appendix H) and can be summarized as follows:

1. Based on a single study in participants requiring intensive lipid lowering therapy, GRADE was “very low” for participants reaching ATP III LDL-c goals for the combination of any dose statin plus BAS compared to any dose statin (Appendix H, Table H-21).
2. Based on a single study in participants followed up for more than 24 weeks, GRADE was “very low” for all cause mortality and participants reaching ATP III LDL-c goals for the combination of any dose statin plus BAS compared to any dose statin (Appendix H, Table H-22).
3. Based on studies in participants regardless of baseline risk and comparing the combination of any dose statin plus BAS to any dose statin, GRADE was “very low” for all cause mortality (3 trials), serious adverse events (2 trials) and participants reaching ATP III LDL-c goals (1 trial) (Appendix H, Table H-23).

### Evidence Summary Tables: Statin Plus Bile Acid Sequestrant Combination Therapy Compared With Statin Monotherapy

Table 41

Quantitative syntheses of longer term outcomes data (clinical, serious adverse events and cancer) for BAS plus statin therapy compared with statin monotherapy

Outcome | Number of trials reporting outcome | Number of participants in relevant treatment groups | Number of participants with events | Odds ratio | Lower CI | Upper CI
All-cause mortality
All trials52,172,185 | 3 | 373 | 2 | 1.07 | 0.11 | 10.51
All trials 24 weeks or more followup52 | 1 | 77 | 1 | 0.35 | 0.01 | 8.9
Trials with adequate allocation concealment172 | 1 | 147 | 1 | 3.25 | 0.13 | 82.24
Fatal Myocardial Infarction
All trials Trial 24 weeks52 | 1 | 150 | 1 | 0.35 | 0.01 | 8.91
Serious Adverse Event(s)
All trials172,198 | 2 | 278 | 7 | 0.39 | 0.06 | 2.36

Abbreviations: BAS = bile acid sequestrant, CI = 95% confidence interval

Table 42

Non-randomized controlled trial evidence regarding BAS plus statin therapy compared with statin monotherapy

Trial | Design Duration Downs and Black score | Patients (LDL-c mg/dL) | Monotherapy Dose (mg/d) | Combination Therapy Dose (mg/d) | Results | Limitations | Applicability | Conclusion
Ojala (1990)88 | CCT 3 years 16/28 | 54 men and postmenopausal women less than 70 years with 1^o^ HC, with or without CHD, and without marked hypertriglyceridemia who had previously participated in a lovastatin-probucol RCT Baseline LDL-c (SD) combination 395 (66)mg/dL mono 240 (39)mg/dL | Lovastatin (max 80mg/d) Titrated in CHD if LDL-c ≥ 120 mg/dL Titrated in others if LDL-c ≥ 140 mg/dL | In patients with LDL-c still above target, colestipol was added and titrated to maximal tolerated dose – lovastatin (80, average dose 74), colestipol (maximum dose 2000, average dose 1200) | Mortality and other clinical outcomes of interest, cancer and cognitive decline NR SAE: Zero patients with in both treatment groups | Groups were not comparable based on type of hypercholesterolemia: non-familial hypercholesterolemia mono, familial hypercholesterolemia combination | Low event rate and lack of reporting of other important long-term outcomes, unknown setting, and patient population are suggestive of low applicability | No comparative analysis can be made given different patient subtypes in the two arms
Mol (1990)89 NR NR | CCT 2 years 13/28 | 26 patients with severe familial hypercholesterolemia Baseline LDL-c (SD) = 342 (68.5) | Simvastatin 40 | S 40 plus C-amine 4000 or colestipol 5000 | Mortality and other clinical outcomes of interest, SAE, cancer and cognitive decline NR Myocardial infarction: S40 = 0/12; S40 + BAS = 1/14 Unstable angina: MI: S40 = 0/12; S40 + BAS = 1/14 CABG/MI: S40 = 0/12; S40 + BAS = 2/14 | No comparison of baseline characteristics was reported | Low event rate, lack of reporting of other important long-term outcomes, unknown setting, and absence of reporting of exclusion criteria are suggestive of low applicability | Results inconclusive given low event rate and lack of statistical significance

Abbreviations: BAS = bile acid sequestrant, CABG = coronary arterial bypass graft, C-amine = colestyramine, CCT = clinical controlled trial, CI = 95% confidence interval, LDL-c = low density lipoprotein cholesterol, N = number, S = simvastatin, SAE = serious adverse events, TG = triglycerides

Table 43

Quantitative syntheses of participants attaining ATP III LDL-c targets, for BAS plus statin therapy compared with statin monotherapy

Outcome | Number of trials reporting outcome | Number of participants in relevant treatment groups | Number of participants with events | Odds ratio | Lower CI | Upper CI
Relative probability of attaining ATPIII LDL-c goal
All trials
Participants requiring intensive lipid lowering therapy | 1 | 59 | 18 | 4.51 | 1.34 | 15.14
All participants with established vascular diseases108

Abbreviations: ATP III = Third Adult Treatment Panel of the National Cholesterol Education Program, BAS = bile acid sequestrant, CI = 95% confidence interval, LDL-c = low density lipoprotein cholesterol

Table 44

Quantitative syntheses of LDL-c data, for BAS plus statin therapy compared with statin monotherapy

Quantitative syntheses | Number of trials reporting outcome | Number in relevant treatment groups | Point Estimate | Lower CI | Upper CI
Difference in mean LDL-c percentage change from baseline
All trials52,52,122,133,163,164,172,172–174,185,191,198 | 11 | 1010
Atorvastatin
Lower dose statin in combination versus higher dose monotherapy133 | 1 | 38 | 5 | −3.34 | 13.34
Participants in need of intensive lipid lowering therapy122,163,174,198 | 4 | 367
Participants with LDL-c>190^122,163,198^ | 3 | 317

Abbreviations: BAS = bile acid sequestrant, CI = 95% confidence interval, LDL-c = low density lipoprotein cholesterol

Table 45

Quantitative syntheses of HDL-c data, for BAS plus statin therapy compared with statin monotherapy

Quantitative syntheses | Number of trials reporting outcome | Number in relevant treatment groups | Point Estimate | Lower CI | Upper CI
Difference in mean HDL-c percentage change from baseline (%)
All trials52,122,163,164,173,174,185,191,198 | 9 | 911 | 0.33 | −1.86 | 2.52
Participants in need of intensive lipid lowering therapy122,163,174,198 | 4 | 367 | 2.25 | −0.56 | 5.06
Participants with LDL>190,122,163,198 | 3 | 317 | 2.37 | −1.18 | 5.93

Abbreviations: BAS = bile acid sequestrant, CI = 95% confidence interval, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol

Table 46

Quantitative syntheses of short term harms and adherence data, for BAS plus statin therapy compared with statin monotherapy

| Number of trials reporting outcome | Number in relevant treatment groups | Number of participants with events | Odds ratio | Lower CI | Upper CI
Treatment adherence
All trials122,133,137,164,190 | 5 | 1420 | 1262
Simvastatin
Lower dose statin in combination versus higher dose monotherapy137 | 1 | 81 | 64 | 0.33 | 0.09 | 1.27
Atorvastatin
Lower dose statin in combination versus higher dose monotherapy133 | 1 | 39 | 35 | 0.94 | 0.12 | 7.48
At least one adverse event
All trials52,122,137,172 | 4 | 522 | 301 | 2.19 | 1.28 | 3.75
All trials 24 weeks or more followup52 | 1 | 150 | 99 | 5.14 | 2.39 | 11.07
Simvastatin
Lower dose statin in combination versus higher dose monotherapy137 | 1 | 83 | 44 | 1.19 | 0.47 | 3.02
Withdrawal due to adverse event
All trials52,122,133,164,172,185,191,198 | 8 | 966 | 31 | 1.80 | 0.68 | 4.76
Atorvastatin
Lower dose statin in combination versus higher dose monotherapy133 | 1 | 39 | 2 | 1.06 | 0.06 | 18.17
AST and/or ALT ≥ 3 times ULN, and/or hepatitis
All trials 185,198 | 2 | 212 | 0
Myalgia
All trials108,122,173,185 | 4 | 343 | 11 | 0.43 | 0.12 | 1.54
CPK ≥ 10 times the ULN
All trials122,198 | 2 | 156 | 0

Abbreviations: ALT = alanine transaminase, AST = aspartate transaminase, BAS = bile acid sequestrant, CI = 95% confidence interval, CPK = creatinine phosphokinase

## Statin Plus Omega-3 Fatty Acid Versus Statin Monotherapy

### Overview of Included Studies

A total of 10 randomized controlled trials trial reports evaluated relative efficacy and/or harms of omega-3 plus statin combination therapy compared with statin monotherapy, in a total of 19212 participants (Table 3; Appendix F, Table F-29 to F-33). It should be noted that the majority of participants was from one study.141 None of the included non-randomized studies addressed this particular comparison. Four randomized trials had more than one associated journal published or FDA report (Table 5). None of the trials had any companion or extension report of longer treatment or followup period.

Two trials were conducted in multiple centers,141,180 and eight trials in single centers (Table 50; Appendix F, Table F-29).107,165,175–179,199 There were no trials exclusively in females, or participants of Hispanic, or African descent.

Reporting of participants' ethnic background was as follows:

- One trial reported a mean of 96 percent of participants of European descent
- Two trials reported a mean of 51 percent of participants of Asian descent (range 1 to 100 percent)
- One trial reported a mean of 2 percent of participants of Hispanic descent
- One trial reported a mean of 1 percent of participants of African descent

Trial duration ranged from five to 240 weeks, with an average of 34 weeks. On average 39 percent of participants were women (range 0 to 78 percent). The average of mean ages of participants was 56 years (range of mean age 47 to 61 years). All trials recruited solely from outpatient settings, with the exception of three in which the recruitment setting was not reported.141,178,179

Of the ten trials, only two trials were exclusively in participants requiring intensive lipid lowering treatment (i.e. participants with established vascular disease and/or diabetes mellitus and/or baseline LDL-c above 190 mg/dL).175,176

The mean Jadad score for trial reports was 3 (range 1 to 4). Four trials involved an appropriate method of randomization,141,175,180,199 while six had an appropriate method of double blinding.107,165,175–177,180 Allocation concealment was reported as adequate in four trials.141,175,180,199

Five of the 10 trials were partially or completely sponsored by the pharmaceutical industry,107,141,176,177,180 while funding was not reported or unclear in five reports.165,175,178,179,199

Distribution of trials by geographical region as follows:

- North America - 2 trials178,180
- Europe - 4 trials165,176,177,179
- Asia - 2 trials141,175
- Australia - 2 trials107,199

### Key Question 1: For patients who require intensive lipid-modifying therapy, what are the comparative long-term benefits, and rates of serious adverse events of coadministration of different lipid-modifying agents (i.e. a statin plus another lipid-modifying agent) compared with higher dose statin monotherapy?

Table 47

Evidence addressing key question 1 for statin plus omega-3 fatty acids versus statin monotherapy comparison

Outcomes | Evidence availability | Key points of evidence synthesis
All-cause mortality | Yes | No significant difference was observed for the outcome in trials in mixed populations (OR 1.08; 95% CI 0.91, 1.28)
Vascular death | No
Fatal myocardial infarction (MI) | Yes | No significant difference was observed for the outcome in trials in mixed populations (OR 0.73; 95% CI 0.34, 1.58) or in participants requiring intensive lipid lowering therapy (OR 0.29; 95% CI 0.01, 7.39)
Non-fatal MI | Yes | No significant difference was observed for the outcome in one 240 week trial comprising of a mixed population (OR 0.75; 95% CI 0.54, 1.03)
Any or unspecified MI | Yes | No significant difference was observed for the outcome in one 240 week trial comprising of a mixed population (OR 0.76; 95% CI 0.56, 1.04)
Acute coronary syndrome (ACS) (encompassing unstable angina or acute MI) | No
Any cerebrovascular event | No
Hemorrhagic stroke | Yes | No significant difference was observed for the outcome in one 240 week trial comprising of a mixed population (OR 1.26; 95% CI 0.83, 1.91)
Ischemic stroke | Yes | No significant difference was observed for the outcome in one 240 week trial comprising of a mixed population (OR 0.93; 95% CI 0.72, 1.21).
Any or unspecified stroke | Yes | No significant difference was observed for the outcome in one 240 week trial comprising of a mixed population (OR 0.42; 95% CI 0.10, 1.87).
Transient ischemic attack (TIA) | No
Carotid endarterectomy (CEA) | No
Percutaneous coronary interventional procedure (PCI) | No
Coronary artery bypass graft procedure (CABG) | No
Any or unspecified revascularization procedure | No
Serious adverse events | Yes | No significant difference was observed for the outcome in one 8 week trial in a mixed population (OR 4.44; 0.49, 40.29)
Cancer | Yes | No significant difference was observed for the outcome in one 240 week trial in a mixed population (OR 1.11; 0.92, 1.34).

Abbreviations: ACS = acute coronary syndrome, CABG = coronary artery bypass graft, CEA = carotid endarterectomy, MI = myocardial infarction, PCI = percutaneous coronary intervention, SAE = serious adverse event

Four trials, randomizing 19002 participants, compared omega-3 fatty acid plus statin combination therapy with statin monotherapy, and reported one or more of the clinical outcomes, serious adverse events or cancer (Table 50).141,176,177,180 There were no trials exclusively in females.

Reporting of participants' ethnic background was as follows:

- One trial reported a mean of 96 percent of participants of European descent
- Two trials reported a mean of 51 percent of participants of Asian descent (range 1 to 100 percent)
- One trial reported a mean of 2 percent of participants of Hispanic descent
- One trial reported a mean of 1 percent of participants of African descent

Trial duration ranged from five to 240 weeks with an average of 69 weeks. Although no trial totally excluded the female gender, on average 42 percent of participants were women (range 27 to 69 percent).

The average of mean ages of participants was 56 years (range 47 to 61 years).

All trials recruited outpatients with the exception of one trial in which recruitment was not reported.141

The mean Jadad score for trial reports was 3 (range 2 to 4), and two trials reports reported an adequate method of allocation concealment.141,180

Of the four trials, only one trial was exclusively in participants requiring intensive lipid lowering treatment (i.e. participants with established vascular disease and/or diabetes mellitus and/or baseline LDL-c above 190 mg/dL).176

#### Long-Term Efficacy, Serious Adverse Events, and Cancer

Comparing statin plus omega-3 fatty acids versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### All-cause mortality

All-cause mortality data was reported for three trials,141,177,180 all of which were in populations not in particular need of intensive lipid lowering and using various statins and doses. Two of these trials presented an adequate form of allocation concealment,141,180 and one trial which had a long-term followup of 240 weeks (Table 50).141 Of the trials, only one yielded analyzable data.141 This trial report demonstrated no statistically significant difference in the incidence of mortality between omega-3 plus statin combination therapy and statin monotherapy, with an odds ratio of 1.08 (95% CI 0.91, 1.28), based 551 events.

##### Myocardial infarction

Incidence of myocardial infarction as well as non-fatal myocardial infarction was reported for one trial,141 which had a followup duration of 240 weeks (Table 50). Fatal myocardial infarction was reported for two trials, which had long-term followup durations of 24 weeks and 240 weeks.141,176

Incidence of myocardial infarction was available for one trial which demonstrated no significant difference between omega-3 plus statin combination therapy and statin monotherapy, with an odds ratio of 0.76 (95% CI 0.56, 1.04) based upon 164 events.141 Non-fatal myocardial infarction data from the same trial demonstrated no statistically significant difference in the incidence of non-fatal myocardial infarction, with an odds ratio of 0.75 (95% CI 0.54, 1.03), based upon 145 events.141

Pooling of fatal myocardial infarction data from two trials demonstrated no statistically significant difference in the incidence of fatal myocardial infarction between omega-3 plus statin combination therapy and statin monotherapy, with an odds ratio of 0.73 (95% CI 0.34, 1.58), based upon 25 deaths.141,176

##### Stroke

Stroke, hemorrhagic stroke and ischemic stroke, were reported for one trial, which had a followup duration of 240 weeks (Table 50).141 There was no significant difference in the incidence of participants with stroke (hemorrhagic or ischemic) between the omega-3 plus statin combination therapy and statin monotherapy, with an odds ratio of 0.42 (95% CI 0.10, 1.87), based upon 328 participants experiencing stroke. This incidence was similar for participants with hemorrhagic stroke (OR 1.26, 95% CI 0.83, 1.91) and ischemic stroke (OR 0.93, 95% CI 0.72, 1.21).

##### Serious adverse events

Data on the incidence of serious adverse events was reported for one trial (Table 50).180 Data from this trial demonstrated that there was no significant difference in the incidence of patients developing a serious adverse event, with an odds ratio of 4.44 (95% CI 0.49, 40.29), based upon five cases.

##### Cancer

Data on the incidence of cancer was reported for one trial (Table 50).141 There was no significant difference in the incidence of patients developing cancer, with an odds ratio of 1.11 (95% CI 0.92, 1.34), based upon 460 cases.

### Key Question 2: Do these regimens differ in reaching LDL-targets (or other surrogate markers), short-term side effects, tolerability, and/or adherence?

Table 48

Evidence addressing key question 2 for statin plus omega-3 fatty acids versus statin monotherapy comparison

Outcomes | Evidence availability | Key points of evidence synthesis
Patients attainting ATP III LDL-c targets | No
LDL-c | Yes | In one trial in a population requiring intensive lipid lowering therapy, no significant difference was noticeable (MD -4.60, 95% CI -16.32, 7.12). Compared with monotherapy, in mixed populations, significantly smaller reduction in LDL-c concentrations with omega-3 plus statin combination than statin monotherapy, (MD 5.26 %; 1.79 %, 8.74 %).
HDL-c | Yes | In one trial in a population requiring intensive lipid lowering therapy, no significant difference were noticeable (MD 1.80; 95% CI -5.61, 9.21). Compared with monotherapy, in mixed populations, significantly greater increase in HDL-c concentrations with omega-3 plus statin combination than statin monotherapy, (MD 5.31 %; 95% CI 3.16, 7.45).
TC:HDL ratio | Yes | In one trial in a population requiring intensive lipid lowering therapy, no significant difference were noticeable (MD -0.41; 95% CI -1.43, 0.61). Compared with monotherapy, in mixed populations, significantly smaller reduction in LDL-c concentrations with omega-3 plus statin combination than statin monotherapy, (MD -7.77 %; 95% CI -10.27, -5.27).
CIMT | No
Treatment Adherence | No
Total adverse events | Yes | Compared with monotherapy, no significant difference was observed for the outcome in mixed populations (OR 1.11; 95% CI 0.82, 1.51). Long-term trials favored monotherapy over combination (OR 1.22; 1.14, 1.31)
Withdrawal due to adverse events | Yes | Compared with monotherapy, no significant difference was observed for the outcome (OR 1.09; 95% CI 0.22, 5.52).
Elevated serum AST and/or ALT > 3 times ULN and/or hepatitis | Yes | No significant difference in the incidence observed for the outcome as there was no reported incidence in either group
Myalgia | No
CPK > 10 times ULN | Yes | No reported incidence in either group
Rhabdomyolysis | Yes | No reported incidence in either group

Abbreviations: ALT = alanine transferase, AST = aspartate transferase, ATP III = Third Adult Treatment Panel of the National Cholesterol Education Program, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, TC = total cholesterol

#### Study Design and Population Characteristics

Ten trials yielded data on participants reaching LDL-c targets and/or other surrogate markers of efficacy, short-term side effects, tolerability, and/or treatment adherence (Table 51 to 54; Appendix F, Table F-23 to F-33).107,141,165,175–180,199

Two trials included participants of Asian descent,141,180 with one trial exclusively in participants of Asian descent.141 One trial included participants of Hispanic descent,180 and one trial included participants of African descent.180

There were no trials exclusively in females, or participants of Hispanic, and/or African descent.

Reporting of participants' ethnic background was as follows:

- One trial reported a mean of 96 percent of participants of European descent
- Two trials reported a mean of 51 percent of participants of Asian descent (range 1 to 100 percent)
- One trial reported a mean of 2 percent of participants of Hispanic descent
- One trial reported a mean of 1 percent of participants of African descent

Trial duration ranged from 5 to 240 weeks with an average of 34 weeks. Only one trial totally excluded the female gender, and on average 39 percent of participants were women (range 0 to 78 percent). The average of mean ages of participants was 56 years (range 47 to 61 years). Seven of the trials recruited outpatients,107,165,175–177,180,199 while three trials did not report recruitment setting.141,178,179 The mean Jadad score was 3 (range 2 to 4) and four trials had adequate allocation concealment.141,175,180,199

Of these 10 trials, only two were exclusively in participants requiring intensive lipid lowering treatment (i.e. participants with established vascular disease and/or diabetes mellitus and/or baseline LDL-c above 190 mg/dL).175,176

#### LDL-c Targets and Other Surrogate Markers

Comparing statin plus omega-3 fatty acids versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### LDL-c, change score from baseline

In participants requiring intensive lipid lowering therapy LDL-c mean change from baseline (change score) was reported for one trial employing similar doses of simvastatin in the two treatment groups (Table 51).175 There was no significant difference in LDL-c reduction in participants on omega-3 plus statin combination therapy compared with statin monotherapy with a mean difference of -4.60 (95% CI -16.32, 7.12).

##### LDL-c, percentage mean change from baseline

The surrogate outcome LDL-c percentage change from baseline was reported for 278 participants in two trials employing identical doses of statins in combination and monotherapy treatment groups (Table 51).107,180 Pooling demonstrated a significantly smaller reduction in LDL-c concentrations with omega-3 plus statin combination than statin monotherapy, with a mean difference of 5.26 (95% CI 1.79, 8.74) favoring statin monotherapy (Figure 63).

##### HDL-c, change score from baseline

In participants requiring intensive lipid lowering therapy HDL-c mean change from baseline (change score) was reported for one trial (Table 52).175 There was no significant difference in changes in HDL-c concentrations between omega-3 plus statin combination therapy and statin monotherapy, with a mean difference of 1.80 (95% CI -5.61, 9.21).

##### HDL-c, percentage mean change from baseline

The surrogate outcome HDL-c percentage change from baseline was reported for three trials (Table 52).107,178,180 Pooling demonstrated a significantly greater HDL-c increase with omega-3 plus statin combination therapy than with statin monotherapy, with a mean difference of 5.31 percent (95% CI 3.16, 7.45).

##### TC:HDL-c ratio, change score from baseline

TC:HDL-c ratio in participants requiring intensive lipid lowering therapy. TC:HDL-c mean change ratio from baseline was reported for one trial (Table 53).175 There was no statistically significant difference between omega-3 plus statin combination therapy and statin monotherapy, with a mean difference of -0.41 (95% CI -1.43, 0.61).

##### TC:HDL-c ratio, percentage mean change from baseline

TC:HDL-c. Two reports presented data for TC:HDL-c ratio percentage change from baseline (Table 53).178,180 Pooling demonstrated a significantly greater decrease in TC:HDL-c concentrations following omega-3 plus statin combination therapy than with statin monotherapy, with a mean difference of -7.77 percent (95% CI -10.27, -5.27).

#### Harms and Treatment Adherence

Comparing statin plus omega-3 fatty acids versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants with at least one adverse event

The incidence of participants experiencing an adverse event was reported for six trials,141,165,176,177,179,180 three of which presented analyzable data (Table 54).141,176,180 Meta-analysis demonstrated no significant difference in the incidence of patients with adverse events following omega-3 plus statin combination therapy compared with statin monotherapy, with an odds ratio of 1.11 (95% CI = 0.82, 1.51). Two trials had a followup duration of 24 weeks or more (range 24 to 240 weeks).141,176 Pooling of the data from these trials demonstrated a significantly higher incidence with omega-3 plus statin combination therapy than with statin monotherapy, with an odds ratio of 1.22 (95% CI = 1.44, 1.31) based upon 4377 participants with events.

##### Rhabdomyolysis

The number of participants with rhabdomyolysis was reported for one trial, with no events in either arm (Table 54).180

##### CPK above 10 times the upper limit of normal

The number of participants with CPK above10 times the upper limit of normal was reported for three trials, with no events in any treatment arm (Table 54).165,177,180

##### Elevated serum AST and/or ALT above 3 times the upper limit of normal and/or hepatitis

The number of participants with elevated serum AST and/or ALT above 3 times the upper limit of normal and/or hepatitis was reported for three trials, with no events in any treatment arm (Table 54).165,177,180

### Key Question 3: Compared with higher-dose statins, and to one another, do combination regimens differ in benefits and harms within subgroups of patients?

Table 49

Availability of evidence addressing key question 3 for statin plus omega-3 fatty acids versus statin monotherapy comparison

[table image]

Abbreviations: Abbreviations: ATP III = the third Adult Treatment Panel III Adult Treatment Panel of the National Cholesterol Education Program, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, TC = total cholesterol

#### Clinical Outcomes

Comparing statin plus omega-3 fatty acids versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### All-cause mortality

###### Participants of Asian descent

One trial presented data regarding all-cause mortality within a subgroup of persons of Asian descent.141 The trial utilized an adequate form of allocation concealment and had a followup of 240 weeks. There was no statistically significant difference in the incidence of mortality between the participants on omega-3 plus statin combination therapy compared with statin monotherapy, with an odds ratio of 1.08 (95% CI 0.91, 1.28) based 551 deaths.

#### LDL-c Targets and Other Surrogate Markers

Comparing statin plus omega-3 fatty acids versus statin monotherapy (lower dose vs. higher dose and various statin doses)

##### Participants with established vascular disease

Evidence was available only for this subgroup.

##### LDL-c mean change from baseline was reported in one trial.175

There was no significant differences in LDL-c concentrations between omega-3 plus statin combination therapy and statin monotherapy, with a mean difference of -4.60 (95% CI -16.32, 7.12).

##### HDL-c mean change from baseline was reported in one trial.175

There was no significant difference in HDL-c concentrations between omega-3 plus statin combination therapy and statin monotherapy, with a mean difference of 1.80 (95% CI -5.61, 9.21).

##### TC:HDL-c ratio mean change ratio from baseline was reported for one trial.175

There was no statistically significant difference between omega-3 plus statin combination therapy and statin monotherapy, with a mean difference of -0.41 (95% CI -1.43, 0.61).

#### Strength of Evidence

The strength of the available evidence was assessed as GRADE (Grading of Recommendations Assessment, Development and Evaluation)225 for the key outcomes all-cause mortality, vascular death, serious adverse events and achieving ATP-III target LDL-c. Results generated using the GRADEpro software are presented in Tables H-12 to H-16 (Appendix H) can be summarized as follow:

1. Based on studies in participants regardless of baseline risk and comparing the combination of any dose statin plus omega-3 to any dose statin, GRADE was “very low” for all cause mortality (3 trials), and serious adverse events (1 trial) (Appendix H, Table H-24).
2. Based on a single study in participants followed up for more than 24 weeks, GRADE was “very low” for all cause mortality for the combination of any dose statin plus omega-3 compared to any dose statin (Appendix H, Table H-25).
3. Based on a single study in participants with of Asian descent, GRADE was “very low” for all cause mortality for the combination of any dose statin plus omega-3 compared to any dose statin (Appendix H, Table H-25).

### Evidence Summary Tables: Statin Plus Omega-3 Fatty Acid Combination Therapy Versus Statin Monotherapy

Table 50

Quantitative syntheses of longer term outcomes data (clinical, serious adverse events and cancer) for omega-3 fatty acid plus statin therapy compared with statin monotherapy

Population | Number of trials reporting outcome | Number of participants in relevant intervention groups | Number of participants with events | Odds ratio | Lower CI | Upper CI
All-cause mortality
All trials141,177,180 | 3 | 18940 | 551 | 1.08 | 0.91 | 1.28
All trials 24 weeks or more followup141 | 1 | 18645 | 551 | 1.08 | 0.91 | 1.28
Adequate allocation concealment141,180 | 2 | 18899 | 551 | 1.08 | 0.91 | 1.28
Participants of Asian descent141 | 1 | 18645 | 551 | 1.08 | 0.91 | 1.28
Fatal myocardial infarction
Participants requiring intensive lipid lowering therapy176
Participants with vascular disease – All trials176 | 1 | 254 | 1 | 0.29 | 0.01 | 7.39
Participants with vascular disease – All trials 24 weeks or more followup176
All trials141,176 | 2 | 18700 | 26 | 0.73 | 0.34 | 1.58
All trials 24 weeks or more followup141,176
Non-fatal myocardial infarction
All trials141
All trials 24 weeks or more followup141 | 1 | 18645 | 145 | 0.75 | 0.54 | 1.03
Unspecified myocardial infarction
All trials141 | 1 | 18645 | 164 | 0.76 | 0.56 | 1.04
All trials 24 weeks or more followup141
Hemorrhagic stroke
All trials141
All trials 24 weeks or more followup141 | 1 | 18645 | 88 | 1.26 | 0.83 | 1.91
Ischemic stroke
All trials141
All trials 24 weeks or more followup141 | 1 | 18645 | 238 | 0.93 | 0.72 | 1.21
Unspecified stroke
All trials141
All trials 24 weeks or more followup141 | 1 | 18645 | 328 | 0.42 | 0.10 | 1.87
Serious adverse events
All trials180 | 1 | 254 | 5 | 4.44 | 0.49 | 40.29
Cancer
Cancer141 | 1 | 18645 | 460 | 1.11 | 0.92 | 1.34

Abbreviations: CI 95% confidence interval

Table 51

Quantitative syntheses of LDL-c data for omega-3 fatty acid plus statin therapy compared with statin monotherapy

Population | Number of trials reporting outcome | Number of participants in relevant intervention groups | Point Estimate | Lower CI | Upper CI
Difference in mean change from baseline
Participants requiring intensive lipid lowering therapy175 | 1 | 40 | −4.60 | −16.32 | 7.12
Participants with vascular diseases175
Difference in mean percentage change from baseline (%)
All trials107,180 | 2 | 278 | 5.26 | 1.79 | 8.74

Abbreviations: CI = 95% confidence interval, HDL-c = high density lipoprotein cholesterol

Table 52

Quantitative syntheses of HDL-c data for omega-3 fatty acid plus statin therapy compared with statin monotherapy

Population | Number of trials reporting outcome | Number of participants in relevant intervention groups | Point Estimate | Lower CI | Upper CI
Difference in mean change from baseline
Participants requiring intensive lipid lowering therapy175 | 1 | 40 | 1.80 | −5.61 | 9.21
Participants with vascular diseases175
Difference in mean percentage change from baseline (%)
All trials107,178,180 | 3 | 297 | 5.31 | 3.16 | 7.45

Abbreviations: CI = 95% confidence interval, HDL-c = high density lipoprotein cholesterol

Table 53

Quantitative syntheses of total cholesterol : HDL-c ratios, for omega-3 fatty acid plus statin therapy compared with statin monotherapy

Population | Number of trials reporting outcome | Number of participants in relevant intervention groups | Point Estimate | Lower CI | Upper CI
Difference in mean change from baseline
Participants requiring intensive lipid lowering175 | 1 | 40 | −0.41 | −1.43 | 0.61
Participants with established vascular diseases175
Difference in changes in mean percentage change from baseline TC:HDL-c
All trials178,180 | 2 | 273 | −7.77 | −10.27 | −5.27

Abbreviations: CI = 95% confidence interval, TC = total cholesterol, HDL-c = high density lipoprotein cholesterol

Table 54

Quantitative syntheses of short term harms and adherence, for omega-3 fatty acid plus statin therapy compared with statin monotherapy

Population | Number of trials reporting outcome | Max dose omega-3 | Number of participants in relevant intervention groups | Number of participants with events | Odds ratio | Lower CI | Upper CI
Relative probability of an adverse event
All trials141,165,176,177,179,180 | 6 | 1800 – 9200 | 19074 | 4491 | 1.11 | 0.82 | 1.51
Trials 24 weeks or longer 141,176 | 2 | 1800 – 4000 | 18700 | 4377 | 1.22 | 1.14 | 1.31
Relative probability of participants withdrawing from treatment due to an adverse event
All trials180 | 1 | 4000 | 255 | 6 | 1.09 | 0.22 | 5.52
Relative probability of participants experiencing elevated serum AST and/or ALT > 3 times the upper limit of normal and/or hepatitis
All trials165,177,180 | 3 | 2000 –4000 | 337 | 0
Relative probability of participants experiencing CPK greater than 10 times the upper limit of normal
All trials165,177,180 | 3 | 2000 –4000 | 337 | 0
Relative probability of participants experiencing rhabdomyolysis (investigator defined)
All trials180 | 1 | 4000 | 254 | 0

Abbreviations: ALT = alanine transaminase, AST = aspartate transaminase, CI = 95% confidence interval, CPK = creatinine phosphokinase

## Applicability of the Body of Evidence for All Comparisons

| Available evidence | Implications
Population | In general studies excluded participants with statin associated myopathy, deranged liver enzymes, high triglycerides, recent vascular events, uncontrolled hypertension, diabetes mellitus and frail elderly over 80 years. Most trials were in mixed CHD risk populations, employed pre-randomization run-in phase to minimize non-adherence, and conducted frequent laboratory monitoring for liver and muscle enzyme elevations to withdraw participants with deranged levels | There is dearth of evidence directly examining comparative effectiveness of treatments. Available evidence mostly compared statin combination therapy with similar or equipotent doses of statin monotherapy and examined relative efficacy using surrogate outcomes over a short-term period. Only one large statin-omega-3 trial can be considered an effectiveness trial, however, this trial examined various statins in various doses in combination and as monotherapy. Direct comparative evidence of clinical effectiveness was also lacking from long-term observational studies
Intervention and comparators | Studies generally employed therapeutic doses of interventions, but few compared addition of another non-statin lipid lowering drug to a statin with the alternative of statin dose escalation
Outcomes | Clinical outcomes except for evident all-cause mortality were infrequently assessed. Nevertheless, all-cause mortality was a rare event across most trials
Followup duration | Most trials were of less than 6 months duration