# 6 Remaining Issues

This review has identified a number of areas requiring future research. Our recommendations address research methodologies in general, and specific needs for research to address the key questions.

All trials must clearly report adequate allocation concealment and intention to treat analysis. Blinding and end point adjudication should be employed to minimize bias. Failure to comply with these standards has adversely affected the quality of trials in this therapeutic area.

Pragmatic trials are required in order to provide relevant guidance to practitioners and patients. In trials of this type oversampling of populations of interest including women, ethnic groups, elderly Americans as well as diabetics would help define the relative applicability of the results. Ample evidence supports the role of LDL-c as a determinant of risk as well as a target for therapy. The current data would support investigation of statin-ezetimibe combinations in this regard. Statin-BAS combinations would also be of some interest though the potential for BAS to interact with other medications by limiting absorption would limit the broad application of these findings. Further research is required to establish the relevance of therapy directed at triglycerides and HDL-c with respect to clinical outcomes. Trials of statin-niacin combination in individuals with low HDL-c in spite of statin therapy and in individuals on maximal statin therapy would serve to define the clinical relevance of these combinations and, at this time, seem more likely to produce relevant data than more broadly inclusive trials for this combination. Similarly, trials of statin-fibrate therapy in individuals with elevated triglycerides are recommended. Omega-3 preparations are variable in content and source with no clear accepted formulation for individuals requiring intensive lipid lowering. While a number of benefits have been suggested, it is unclear that statin-omega 3 combination preparations have any benefits over higher dose statins in this population based on the negative data to date. Further investigation of these combinations should focus on optimizing the formulations and establishing added clinical benefit when used in maximally treated populations. The following points apply to the proposed trials of combination therapy and serve to amplify these comments in the context of the Key Questions.

## Key Question 1: For patients who require intensive lipid-modifying therapy, what are the comparative long-term benefits, and rates of serious adverse events of coadministration of different lipid-modifying agents (i.e. a statin plus another lipid-modifying agent) compared with higher dose statin monotherapy?

1. The comparator for trials of combination therapy in which LDL-c reduction or clinical events are a major outcome should be a higher dose statin. The bulk of the clinical evidence for this endpoint as well as clinical endpoints exists for statin monotherapy. Until a compelling case can be made for a particular combination therapy, comparisons with similar doses of statin monotherapy are unhelpful in resolving the issue.
2. Studies of combination therapy should be conducted over longer time periods and be powered for clinical endpoints. Since the lipid lowering treatment is usually required for life, both trial treatment and observation duration should be of longer duration. The current evidence base lacks trials of this type, significantly limiting the conclusions which can be drawn. The specific duration will be determined by the endpoints and the risk profile of the population studied but, in general, studies of less than 2 years are unlikely to add significantly to the evidence base on clinical outcomes.
3. Harms should be prospectively collected and comprehensively reported. Short duration trials are unlikely to accrue sufficient adverse events, particularly those with longer latency periods such as cancer.
4. As the possibility of harm cannot be excluded for some individuals with symptomatic cerebrovascular disease due to the unique risk for cerebral hemorrhage in these individuals, this population should be specifically studied in order to better define the parameters for those in whom intensive combination therapy is recommended.
5. Concomitant and antecedent therapy should be explicitly stated as both of these factors may influence outcomes. In studies employing a mixture of statin medications and/or doses, results should be reported by medication and dose in order to allow pooling across studies.
6. Studies investigating HDL-c and non-HDL-c targets in a population with LDL-c at target are recommended. The absence of such evidence limits the ability to assess the role of combination therapies which raise HDL-c levels.

## Key Question 2: Do these regimens differ in reaching LDL-targets (or other surrogate markers), short-term side effects, tolerability, and/or adherence?

1. The comparator for trials of combination therapy, with LDL-c reduction as a primary outcome, should be a higher dose statin as noted above.
2. Studies to correlate LDL-c with CIMT and clinical outcomes should be conducted in different populations (e.g. participants with diabetes mellitus, CHD, and multiple risk factors as defined by ATP III), with reporting of antecedent therapy as this may be a determinant of outcome. Such work would help further validate CIMT as a suitable surrogate marker for future trials.
3. As medication adherence and persistence are important determinants of outcome and are correlated with the complexity of the treatment regimen, studies should be undertaken to compare combinations delivered as a single pill as opposed to two separate ones.
4. Measures of adherence and persistence are affected by the duration of the study period and thus longer term trials are required for combination therapies of lipid modifying agents. Trial durations of greater than six months and preferably one year are recommended.

## Key Question 3: Compared with higher dose statins, and to one another, do combination regimens differ in benefits and harms within subgroups of patients?

1. Trials should be conducted in, or over sample, specific subgroups in order to determine relative benefits and harms of a statin combination compared with statin monotherapy. These groups include women, older individuals more susceptible to harms of drug therapy, participants with diabetes mellitus and multiple risk factors, and those of African, Hispanic and Asian descent.
2. Trials including women and the groups identified above should report results in a manner amenable to extraction and pooling in order to permit the early identification of a differential effect in specific subgroups. Specifically, whenever possible, results should be reported by subgroups in trial publications.