# 2 Methods

## Topic Development

The topic for this evidence report was nominated in a public process. With input from technical experts, the Scientific Resource Center (SRC) for the AHRQ Effective Health Care Program selected and refined the questions to be addressed. Initial questions were posted on a website for public feedback. Investigators at the University of Ottawa Evidence-based Practice Center, including a lipidologist and clinical specialists in relevant fields, further refined the questions with the assistance of the SRC and AHRQ.

## Search Strategy

Initial and updated searches for the review were conducted in MEDLINE (1966 to August Week 3 2008), EMBASE (1980 to 2008 Week 36) and CENTRAL (The Cochrane Library, 3rd Quarter 2008) using the Ovid interface, and limited to English language publications from 1980 or later. Searches were also conducted for subsequent publication of trials identified in U.S. Food and Drug Administration (FDA) reports, and to seek longer term followup. Citing reference searches were performed on expert nominated references using Scopus, to identify missed trials and longer-term follow-up.21,46–52 An updated and expanded search to capture observational studies (i.e. without an RCT filter and without date limits) was conducted in MEDLINE (1950 to August Week 3 2008). The search strategies for each database are presented in Appendix A.

Serious or rare harms were sought by searching for named harms – neoplasms, rhabdomyolysis, myocardial infarction, liver failure and stroke, by searching for harm related terms, and by searching for publications arising from administrative databases.53,54 Certain harms specified in the protocol (rhabdomyolysis, stroke, myocardial infarction, cancer, liver failure and death) were sought using the relevant search terms. In order to detect unexpected serious or rare harms, harm-related terms were assembled from research on information retrieval of etiology and harms55–57and from previous AHRQ evidence reports.58,59 Administrative databases included prescription claims databases, health care utilization, hospital discharge and practice-based databases and regional, and national and international surveillance systems. The search for reports from administrative databases included database names nominated by the Scientific Resource Center (personal communication, Nancy Brown SRC Research Librarian, 8/22/2006), and derived from a systematic review of biotherapeutics surveillance,60 a previous published report of harms with statin uses,61as well as relevant subject headings.

Additional material from the SRC or obtained through a search of regulatory agency websites included:

- FDA-posted statistical and medical reviews of new and amended drug applications (ezetimibe, fenofibrate, colesevalam, atorvastatin, rosuvastatin, pravastatin, lovastatin, fluvastatin, simvastatin, advicor (niacin/lovastatin), and vytorin (ezetimibe/simvastatin))
- scientific information packages submitted by industry: Abbott (fenofibrate-statin and niacin-statin combinations); Merck (simvastatin, ezetimibe and vytorin); AstraZeneca (rosuvastatin in combination with other agents).
- grey literature reports from internet searches.

Authors of included reports were also contacted for data clarification and additional data as needed, within a pre-specified time frame. When authors passed our data requests to a third party, we included only data that was returned from the third party via one of the authors. This process of additional data acquisition was facilitated by the SRC.

## Study Selection

Study selection was based on predefined eligibility criteria of interventions, patient populations, outcome measures, and study design (Table 2). The electronic literature search, hand search, and expert-nominated records, were uploaded to the software program SRS version 4.0 (Trialstat), along with screening questions developed by the review team. Titles and abstracts were screened by one reviewer for potential relevance, and exclusions at this level were verified by a second reviewer. If there was disagreement or uncertainty about relevance, the record was passed through to the next level for full-text review. Two reviewers reviewed full text reports independently, applying a priori eligibility criteria. Discrepancies were resolved through discussion and consensus or by third party adjudication if consensus could not be reached. Reviewers were not masked to the reports‘ authors, institution or journal. Studies that were available only as abstracts or conference proceedings and publications that reported study design or rationale only were excluded, as were letters and editorials.

Table 2

Inclusion and exclusion criteria

Population | Adults, including healthy participants
Interventions | Included; - statin plus another hypolipidemic drug versus statin monotherapy with or without placebo (direct comparisons); - statins - atorvastatin, simvastatin, fluvastatin, pravastatin, lovastatin, simvastatin; - nonstatin medications - ezetimibe, fibrates, niacin (IR, SR or ER), BAS or omega-3 fatty acids; Excluded; - cerivastatin, mevastatin, and pitavastatin; - clofibrate, cirprofibrate and bezafibrate; - colestimide; - statin plus thiazolidinediones; - statin plus cholesterol ester transferase inhibitor; - statin plus plant stanols/sterol; - any eligible drug in non-therapeutic or unapproved doses; - any non-approved investigational agent of one of the above drug classes
Outcomes | Clinical:; - all-cause mortality, vascular death,; - fatal MI, non-fatal MI, any or unspecified MI, ACS (unstable angina or acute MI),; - hemorrhagic stroke, ischemic stroke, any or unspecified stroke, TIA, any cerebrovascular event; - CEA, PCI, CABG and any or unspecified revascularization procedure; Surrogate:; - NCEP ATP III LDL-c target attainment, LDL-c, HDL-c, TC:HDL-c ratio; - non-HDL-c and triglycerides in subgroup with diabetes mellitus; - measures of carotid or coronary atherosclerosis (arterial intima-media thickness, plaque area, plaque volume, arterial calcification and/or measure of stenosis); Harms:; - treatment adherence (investigator defined),; - participants experiencing at least one adverse event, serious adverse event (explicitly stated), withdrawal due to an adverse event, cancer, elevated serum AST and/or ALT ≥ 3 times ULN and/or hepatitis, myalgia, CPK ≥ 10 times ULN, and rhabdomyolysis (investigator defined)
Study design | Included - Directly comparative studies; - RCT and; - NRS if over 24 weeks duration, and investigating clinical outcomes, SAE or cancer; Excluded; - other observational designs; - indirect comparisons; - crossover trials with fewer than 4 weeks washout; - crossover trials without paired observations, within-person differences, nor pre-crossover data.
Publication | Exclude: non-English publication, editorials, full text not presented or unavailable.

Abbreviations: ACS = acute coronary syndrome, ALT = alanine transaminase, AST = aspartate transaminase, BAS = bile acid sequestrants, CABG = coronary artery bypass graft, CEA = carotid endarterectomy, CPK = creatine phosphokinase, ER = extended release, HDL-c = high density lipoprotein cholesterol, IR = immediate release,, LDL-c = low density lipoprotein cholesterol, MI = myocardial infarction, NCEP ATP III = National Cholesterol Education Program Adult Treatment Panel III, NRS = nonrandomized study, PCI = percutaneous coronary intervention, RCT = randomized controlled trial, SAE = serious adverse events, SR = slow release, TC = total cholesterol, TIA = transient ischemic attack, ULN = upper limit of normal

### Population and Health

Studies that enrolled adults (18 years of age and above) who were candidates for intensive lipid-modifying therapy were included. For the purposes of the review, an indication for intensive lipid-modifying therapy was defined on the basis of an estimated risk of greater than 20 percent for developing major cardiovascular events over 10 years, based on the Framingham global risk equations for major cardiovascular events, and according to the risk categories of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III).62 Patients at high risk have either established coronary heart disease (CHD) (candidates for secondary prevention), multiple risk factors or CHD risk equivalents (candidates for primary prevention). Since individual participant risk assessments are not routinely reported, CHD risk equivalence was considered when one or more of the following criteria were met for all trial population or trial subgroups(s):

- report explicitly stated CHD risk equivalent status of trial population as per NCEP ATP III criteria
- participants were reported to have prior established coronary or carotid artery disease
- participants were reported to have prior established peripheral arterial disease
- participants were reported to have prior abdominal aortic aneurysm
- participants were reported to have diabetes mellitus

Adults with isolated hypercholesterolemia and a very high LDL-c (190 mg/dL and above), generally associated with genetic forms of hypercholesterolemia, were also considered to be candidates for intensive lipid-modifying treatment due to the magnitude of LDL-c reduction required to reach target goals, at least below 160 mg/dL.

Studies that enrolled patients with lower or mixed 10-year CHD risk levels were also included since we anticipated little evidence strictly in populations of interest, and also as we aimed to explore incremental benefits of adding a non-statin drug to statin therapy with the totality of available evidence. However, we did not specifically examine the effect of adding a non-statin lipid lowering drug in participants already receiving maximally tolerated statin doses.

We identified those subgroups of the population in need of intensive lipid lowering that were likely to be reported as trial level covariates. Included were clinical populations that qualified as high-risk according to NCEP ATP III as explained above. Additionally, we considered those with severe hypercholesterolemia likely to require intensive lipid lowering, adult populations more vulnerable to treatment harms,63 females, and distinct minority ethnic populations. Thus, the subgroups included:

- participants with baseline LDL-c above 190 mg/dL
- participants with diabetes mellitus (type 1 or type 2)
- participants with established vascular disease
- participants with cerebrovascular disease
- African, Asian and Hispanic racial/ethnic groups
- women
- the elderly, 80 years of age and above

### Interventions and Comparators

The comparison of interest was statin plus another lipid-modifying therapy versus statin monotherapy (with or without a placebo). Studies that assessed the six current FDA-approved statins (atorvastatin, lovastatin, fluvastatin, simvastatin, rosuvastatin and pravastatin) were eligible.

Relevant combinations included one or more of the eligible statins mentioned above, combined with one of the following in any FDA approved dose:

- niacin (immediate, slow or extended release)
- peroxisome proliferator-activated receptor alpha (PPARα) agonists; i.e. fibric acid derivatives (gemfibrozil, fenofibrate, micronized fenofibrate)
- a specific cholesterol absorption inhibitor (ezetimibe)
- bile acid sequestrants (colesevelam; colestipol; cholestyramine)
- omega-3 (ω-3) polyunsaturated fatty acids [e.g. eicosapentaenoic acid (EPA; 20:5 n-3), decosahexanoic acid (DHA; 22:6 n-3) and docosapentaenoic acid (DPA; 22:5 n-3)]. Omega-3 fatty acids studies were eligible if they administered Omacor,^®^ or dietary supplements or fish oils in which the amount and type of omega-3 fatty acid was reported.

Fixed dose combinations administered as single oral medications were included, as well as combinations administered separately. Extended release forms of medications such as fluvastatin (lescol XL), lovastatin (altocor) and niacin (niaspan) were considered as well as immediate release forms. As the number of trials comparing lower statin doses in combination therapy with higher dose monotherapy was expected to be small, trials comparing similar doses of statins were included in the initial analyses.

Medications were excluded if they have been withdrawn from the market, were approved only outside of North America, or were investigational drugs or statin combinations (Table 2).

Since pharmacodynamic pleiotropy, variable lipohilicity and drug interactions are noted for statins,64,65 individual as well as statin class effects were investigated.

### Outcomes of Interest

Predefined clinical and surrogate outcomes, and outcomes of harms considered for data extraction and syntheses are summarized in Table 2.

We considered all-cause mortality and vascular death to be the primary outcomes. We also considered the composite outcome of vascular death plus non-fatal MI plus non-fatal stroke, but our preliminary review of the included studies indicated that this outcome was reported infrequently. Further, since only summary trial data were available, it was not possible to ascertain whether the number of participants with events was equivalent to the reported number of events because one participant may have experienced multiple non-fatal events. Thus, summing a dichotomous composite outcome from individual outcome data may introduce a ‘unit of analysis’ error. The composite outcome, therefore, could not be estimated for trials.

Clinical outcomes, ATP-III LDL-c target attainment, and harms outcomes were considered as dichotomous instead of count data (i.e. time-to-event data). Therefore, the proportion of participants with at least one event, and not the number of events constituted the aforementioned dichotomous outcomes.

Continuous data can be analyzed either as post-treatment score, absolute difference (or change score) from baseline, or as percentage change from baseline.66 Percentage change from baseline was considered to be the primary statistical data for synthesis because randomization may not eliminate baseline imbalance (this is particularly so in small trials). Change score was used only when percentage change data were not available.

### Types of Studies

We anticipated that study populations in studies comparing combination therapy with statin monotherapy would likely include more participants with severe dyslipidemia, combined dyslipidemia, inadequate response to prior statin treatment, and/or previous intolerance to maximal statin doses, compared with populations in statin monotherapy studies. With this high probability of differences in study populations, we did not carry out indirect comparisons.

Thus the following study designs were included only if they permitted a direct, head to head comparison of combination versus statin monotherapy:

1. Parallel (including factorial) randomized controlled trials (RCTs)
2. Crossover trials
3. Non-randomized studies (NRS) that were quasi-experimental controlled clinical trials (CCT), and prospective or retrospective cohort studies, nested case-control and case-control studies, and cross-sectional studies.

For effects on lipid levels and short-term harm outcomes, we included head to head comparator RCTs of combination therapy versus statin monotherapy of any sample size, duration or followup, but more importance was given to longer duration, well-conducted trials that reported clinical effectiveness.

For all-cause mortality, vascular death, major cardiovascular outcomes, serious adverse events, and cancer we anticipated that the available RCT data would be of inadequate followup duration to capture these rare events and decided a priori to include evidence from eligible NRSs that were 24 weeks or longer in followup.

We did not define inclusion or exclusion criteria with regards to a diet requirement or a washout period for previous medications prior to initiation of the study.

## Data Extraction

Published data were extracted by members of the research team (KS, AA, MA). Extracted data were checked for gross inaccuracies by one reviewer (AA), and 30 percent of the data were randomly and independently verified by another member of the research team (MSe). FDA and scientific information package data were identified and extracted by one reviewer (MSe), and both were independently verified by another (FY). Minimal, data accuracy checks were additionally undertaken during the process of data syntheses.

Standardized and comprehensive online electronic data extraction forms were developed using SRS. Data extraction forms were piloted with three studies and identified issues were resolved. Descriptive data, outcomes, subgroup, and quality assessment data extracted included: general study characteristics (e.g. study design and duration); population characteristics (e.g. age, gender and race/ethnicity); interventions and dosing regimens including whether conditional titration was utilized; numbers of patients randomized into relevant treatment groups; outcomes measured, method of ascertainment and the results of each outcome, including measures of variability, by relevant intervention arm. Funding source was also noted.7

When there were multiple reports of the same study we referenced the primary or most relevant studyin this report, and extracted only additional or extension phase data from companion reports. Corresponding authors were contacted for data clarification and missing data, but assumptions were not made for imputation. Furthermore, data were not imputed when they were only represented graphically. When relevant data for multiple followup/observation periods were reported, only the longest available followup data were extracted and used.

Complex data queries were conducted using the Structured English Query Language (SQL) functionality of the ACCESS program after a pilot test was refined.

### Details of Data Extraction

Dichotomous data were extracted either as the number (n) of participants with events and the total number evaluable (N) or as summary between treatments (combination versus statin monotherapy) with 95 percent confidence interval (CI). Continuous outcomes were extracted as the mean (percentage change or change score) with the accompanying measure of dispersion for each treatment group, or as a mean difference between treatments.

Some trials reported a common range of numbers of evaluable participants for the outcomes in the table of results. In such cases, the lower bound of the range was extracted as N for all relevant outcomes.

When trials incorporated multiple relevant treatment arms, data from all were extracted. We noted whether extracted data belonged to a specific statin type and dose or was pooled across doses.

In order to standardize treatment followup from different trial reports, we considered one month to be equivalent to four weeks and recorded all followup periods in weeks. Only relevant trial data were extracted and synthesized. For example, if a trial randomized participants to placebo, niacin, statin plus niacin, and statin alone, only data pertaining to the last two treatments were extracted. Trials reported variable drug dosing regimens. We used the following guidance: fixed dosing was considered to occur when participants were assigned to a specific dose of drug treatment and continued throughout the trial duration. In fixed titrated dosing schedule, the drug dose was increased to a maximum in all participants. A conditional titration required only a select group not meeting pre-stated cholesterol or LDL-c criteria to be titrated to the next higher drug dose. In trials that employed fixed or conditional titration, the maximum statin dose was extracted for treatment group identification and the type of dosing regimen was noted.

When reports did not explicitly state or allow clear inference of a dichotomous outcome, data was not assumed. For example, when all-cause mortality was not reported but it was stated that there were no serious adverse events, we recorded all-cause mortality as zero (i.e. no mortality). However, when neither all-cause mortality nor serious adverse events were reported, and it was not clear whether or not all participants completed the trial, all-cause mortality was not extracted. Adherence data were also extracted, if available, as a binary outcome (e.g. participants who were adherent) according to the definition provided in the respective trial reports.

### Data Extraction of Crossover Trials

With respect to crossover trials, we regarded a minimally sufficient washout period to be four weeks. When carryover effects were analyzed and reported, the estimate had to be statistically nonsignificant. Further, crossover data were considered for extraction and syntheses only when standard deviation, standard error or confidence interval for the within-person differences were reported (or were obtained from authors) for continuous outcomes; or dichotomous data were based on paired observations from the same individual.67 If relevant crossover data were not available, only pre-crossover data were extracted and synthesized. If neither, then the study was excluded because no data imputations were attempted.

### Data Extraction of LDL-c

The broad-cut LDL-c fraction based on beta-quantification reference method recommended by NCEP as the evaluating standard has been epidemiologically linked to cardiovascular diseases.68–70 LDL-c (indirectly) calculated with the commonly employed Friedewald‘s formula agrees with β-quantification reference method up to triglyceride (TG) levels of 400 mg/dL. However, at higher TG levels (as in diabetes and non-fasting states) estimation of LDL-cholesterol by this method is not accurate.68,69,71 The NCEP recommended that laboratories employ LDL-c assays with a total analytical error < 12 percent, imprecision < 4 percent, and inaccuracy < 4 percent.71 New (third) generation of homogeneous assays directly measuring LDL-c offer the capability for fully automated measurement of LDL-c.72

When studies reported both direct and indirectly measured LDL-c, we extracted indirectly measured LDL-c when TG < 400 mg/dL or patients were fasting. Otherwise direct LDL-c was extracted. Since it was ensured that extracted indirect LDL-c data pertained to adequately fasted blood samples, indirect LDL-c data were considered valid estimation of true LDL-c (adequate fasting). We, therefore, did not distinguish between direct and indirect LDL-c measurements in quantitative or qualitative syntheses and heterogeneity assessments.

### Unit Conversion

Biochemical data reported in SI units (e.g. LDL-c in mmol/L) were converted to mg/dL. The conversion factor for LDL-c, HDL.c and non-HDL-c was 38.7 mg/dL per mmol/L. The conversion factor for triglycerides into mg/dL was 88.6 mg/dL per mmol/L.73

### Definition of Serious Adverse Event

We stipulated that only explicitly stated serious adverse events (SAE) be extracted. The U.S. FDA defines a serious adverse event (SAE) as any untoward medical occurrence that at any dose:

- results in death;
- is life threatening;
- requires inpatient hospitalization or prolongation of existing hospitalization;
- results in persistent or significant disability/incapacity; or
- results in a congenital anomaly or birth defect.

### Identification of Trial Data

Trials were identified by first author and year of publication. When the same first author published two different trials in the same year, trial data for a common outcome were differentiated as follows:

- author year_a
- author year_b

## Quality Assessment

We used predefined criteria to evaluate the quality of included studies. Reports of RCTs were assessed using the Jadad scale, a 5 point scale that evaluates sequence generation (randomization), blinding, withdrawals and dropouts.74 Studies scoring 3–5 on the Jadad scale are considered to be of higher quality than studies scoring 0–2. Adequacy of allocation concealment was assessed as adequate, inadequate or unclear.75

The quality of non-randomized studies was assessed using the Downs and Black criteria.76 The final question of the Downs and Black instrument was operationalized to a 0 or 1 score (from a 0–5) depending whether a power or sample size calculation was reported (1) or not (0). The total Downs and Black score ranged from 0–28 with higher scores indicative of less bias.

A trial was considered to have employed intention-to-treat (ITT) analysis when data were analyzed for all randomized participants in the treatment groups to which they were originally randomized.77 If the number of participants associated with the outcome data were not clear, then authors‘ statement that ITT analysis was employed was considered to be sufficient evidence.

## Applicability

The clinically important outcomes, study durations, setting, participant characteristics and country of origin are reported in the results.

Applicability of evidence distinguishes between effectiveness studies conducted in primary care or office-based settings that use less stringent eligibility criteria, assess health outcomes, and have longer followup periods than most efficacy studies. The results of effectiveness studies are more applicable to the spectrum of patients in the community who will use combinations of lipid-modifying agents, than efficacy studies in highly selected populations.

## Rating the Body of Evidence

The overall strength of evidence for outcomes was assessed using a method developed by the GRADE Working Group.78 Rating the body of evidence incorporates the following key elements: study design, study quality, consistency and directness, and also considers the presence of imprecise or sparse data, probability of publication bias, evidence of a dose gradient effect where applicable and magnitude of the effect. Quality of syntheses or the body of evidence are rated to indicate the level of confidence that can be placed on the summary findings:

- “high” means that further research is very unlikely to change our confidence in the estimate of effect
- “moderate” means that further research is likely to have an important impact on our confidence in the estimate of the effect and may change the estimate
- “low” means that further research is very likely to have an important impact on our confidence in the estimate of the effect and is likely to change the estimate.
- “very low” means that any estimate of effect is very uncertain.

A detailed explanation of the parameters used to grade the evidence and their operationalization are summarized in Appendix H.

The GRADEpro software was used on four select important outcomes of interest for the key questions.79 The outcomes chosen for grading the strength of evidence were:

- all-cause mortality
- vascular death
- participants experiencing a serious adverse event
- participants attaining ATP III LDL-c goals

## Evidence Synthesis

Quantitative syntheses were attempted to answer the key questions. In the case of substantial statistical heterogeneity (defined below), we did not proceed with the meta-analysis. Exploration of heterogeneity was undertaken qualitatively as per the following guidance:

- explore heterogeneity when I2 was above 50 percent, and the number of studies was greater than five
- remove extreme outliers where applicable and re-run meta-analysis
- explore heterogeneity qualitatively based on a limited number of important and pre-defined covariates or effect modifiers

We defined effect modifiers that were considered important to explain heterogeneity. These included 10-year CHD risk (i.e. low/moderate/mixed risk trials versus high risk trials); sponsorship (nonindustry versus industry); statin dose (trials employing statin doses of similar strength or potencies in combination and monotherapy arms versus those employing lower statin doses in combination therapy and higher statin doses or potencies in monotherapy); trial duration (fewer than 24 weeks versus those of 24 weeks or longer duration); and allocation concealment (trials with adequate allocation concealment versus those with inadequate/unclear allocation concealment).

### Planned Analyses

Data analyses were carried out to evaluate: (1) efficacy/effectiveness; and (2) adverse events and adherence. Each statin was considered separately in comparisons using each of the five possible non-statin medications (ezetimibe, niacin, fibrates, bile acid sequestrants and omega-3 fatty acids) in combination therapy.

Nonrandomized studies (NRSs) were synthesized qualitatively, as meta-analysis of them is controversial.80–82 Furthermore, estimates from individual studies are often adjusted for confounding, which may vary across studies. Diversity in study designs, patient characteristics and measurement of outcome variables in NRSs are further factors impeding quantitative summary estimation. Instead, we chose to appraise the quality of the evidence and to explore its strengths and limitations.

For Key Question 1, the primary outcomes of interest were long-term clinical outcomes, serious adverse events and cancer. Based on our preliminary review of the RCT literature, we considered long-term to be study duration of 24 weeks or longer. Evidence from both randomized and NRSs was considered. For Key Question 2, focusing on short-term intermediate measures of efficacy and harm, evidence syntheses were restricted to RCTs. For Key Question 3, both RCT and NRS evidence were considered.

Dichotomous summary estimates were reported as odds ratios with 95 percent confidence interval (CI), and continuous surrogate biochemical outcomes were pooled as differences in means of percentage change from baseline, and when not available, difference in mean change scores.

The key questions focused on the population in need of intensive lipid lowering therapy, and subgroups. Questions also entailed that the statin used in combination therapy be of a lower dose than statin monotherapy. We anticipated sparse evidence in these populations, especially investigations of lower dose combination statin versus higher dose statin monotherapy. As such we employed the following general approach in evidence syntheses (see Planned analyses, Appendix D):

- synthesize evidence related to various statins and doses across all available populations. (Does addition of another drug to statin therapy offer a common incremental benefit across various populations?)
- synthesize evidence pertaining to lower dose of a specific statin in combination with another lipid modifying drug, and higher dose of the same statin as monotherapy, across all available populations – atorvastatin, simvastatin and rosuvastatin were considered in this dose and statin specific analysis. (Is adding another lipid lowering drug better than increasing the statin dose across various populations?)
- synthesize evidence related to various statins and doses in participants requiring intensive lipid lowering and subgroups
- synthesize efficacy/effectiveness evidence pertaining to a lower dose of a specific statin in combination with another lipid modifying drug, compared with higher dose monotherapy using the same statin, in participants requiring intensive lipid lowering and in subgroup population – atorvastatin, simvastatin, rosuvastatin, pravastatin, lovastatin and fluvastatin were considered in this dose and statin specific analysis.

For each of these syntheses associated with clinical outcomes and serious adverse events, we conducted sensitivity analyses on trials of long-term duration, and trials with reports of adequate allocation concealment for the outcomes of all-cause mortality and vascular death.

Thus, all-cause mortality, vascular death and surrogate efficacy outcomes were examined for all trial populations, populations in need of intensive lipid lowering, and subgroups. However, anticipating availability of insufficient evidence pertaining to specific populations, synthesis of evidence on harms and clinical outcomes, other than the primary outcomes of all-cause mortality and vascular death, was undertaken irrespective of population characteristics (i.e. across all trials or mixed populations) for each combination versus monotherapy comparison.

### Population in Need of Intensive Lipid Lowering and Subgroups

To synthesize evidence regarding those in need of intensive lipid lowering therapy, data were considered from trials restricted to, or providing subgroup data on, those with CHD, CHD risk equivalent disease (as per NCEP ATP III criteria), and/or baseline LDL-c equal to or above 190 mg/dL. Subgroup analyses focused on participants with/of:

- baseline LDL-c ≥ 190 mg/dL
- diabetes mellitus
- established vascular disease – i.e. subgroup or full trial data on those with peripheral vascular disease, cerebrovascular disease, and/or established CAD
- cerebrovascular disease – i.e. subgroup or full trial data on those with ischemic stroke, hemorrhagic stroke, unspecified stroke and/or TIA
- African descent
- Asian descent
- Hispanic profile
- women
- participants ≥ 80 years of age

### Operationalizing Lower Dose Statin in Combination with Another Hypolipidemic Drug Versus Higher Dose Statin Monotherapy

Given the absence of bioequivalence studies across different statins, comparison of lower dose statin in combination therapy with higher dose statin monotherapy was statin specific. In order to avoid multiple comparisons across numerous permutations of lower versus higher dose statins, lower and higher statin doses were defined a priori as follows:

Statin | Atorvastatin | Simvastatin | Rosuvastatin | Pravastatin | Fluvastatin | Lovastatin
Lower dose (mg/day) | 5 and/or 10 and/or 20 | 5 and/or 10 and/or 20 | 5 and/or 10 | 5 and/or 10 and/or 20 and/or 40 | 5 and/or 10 and/or 20 and/or 40 | 5 and/or 10 and/or 20 and/or 40
Higher dose (mg/day) | 40 and/or 80 | 40 and/or 80 | 20 and/or 40 and/or 80 | 80 | 80 | 80

### Trials with Multiple Intervention Arms

More than a quarter (28%) of the trials compared different doses of statins in combination or alone incorporating multiple intervention arms. In the example below two categories of such trials with balanced or unbalanced intervention arms are presented.

How data from treatment arms were included in the evidence synthesis is depicted above. When the number of treatment arms were unbalanced between combination and monotherapy groups within a trial, heterogeneity between arms (but within trial, within treatment group) was assessed using Fisher’s Exact test or Chi-square test for dichotomous outcomes, and generic inverse variance methods for continuous outcomes. When between-arms heterogeneity was not significant or substantial (i.e. p ≥ 0.05 for Fisher’s Exact test or Chi-square test, and I2 ≤ 50%), continuous data were pooled using generic inverse variance, and binary data were pooled by summing the numerators and the denominators of corresponding proportions. Pooled treatment group data from this trial were then used in the meta-analysis.

When pooling was not possible or not applicable (as in the case of a balanced trial), highest of the lower statin doses in combination arm was compared with the highest (e.g. atorvastatin 80 mg) of the available higher doses (in monotherapy arm) for the dose and statin specific analysis. The lower and higher doses of the statins were predefined as mentioned above. For the various statins and doses analysis, treatment arms with identical (or closer) doses were compared as shown for the balanced trial.

In the forest plot, multiple treatment arm data from the same trial were presented as separate comparative estimates, and identified as single trial evidence as per the following identification for the atorvastatin example:

- author 2008_1 A 10 combination therapy versus A10 monotherapy
- author 2008_2 A 20 combination therapy versus A 20 monotherapy
- author 2008_3 A 40 combination therapy versus A 40 monotherapy
- author 2008_4 A 80 combination therapy versus A 80 monotherapy

### Meta-Analysis and Publication Bias

Data from crossover trials were combined with parallel design trials only when the appropriate paired or precrossover data were available. Heterogeneity across trials was tested using an I2 statistic,83 with an I2 value greater than 50 percent considered to be substantial, thereby precluding quantitative pooling across studies.

Meta-analyses were based on the random effects model of DerSimonian and Laird,84 except for those binary outcome meta-analyses in which the percentage of participants with an event was less than one percent, in which case Peto‘s odds ratio was calculated using a fixed effects model. The Comprehensive Meta-Analysis software version 2.2046 was used to complete all meta-analyses.

In addition to the sensitivity analyses focusing on long-term trials, additional analyses of the adequacy of allocation concealment for the main outcomes of all-cause mortality and vascular death were under taken to estimate robustness of findings.85

Dose and statin specific meta-analyses (i.e. lower dose of a specific statin in combination with another lipid lowering drug compared with higher dose monotherapy using the same statin) were considered both regardless of mode of dosing (fixed dose, fixed titrated, or conditionally titrated dosing) and those restricted to trials employing fixed dose or fixed titrated dosing regimens.

Dichotomous data with zero values (e.g. no participant experiencing myalgia) were not included in meta-analyses because summary trial results were not estimable, but such trials, with their evaluable sample, were reported in the particular synthesis.

For surrogate outcomes, some studies reported effect estimates as adjusted means (least square mean), usually from an ANCOVA model. The covariates adjusted for included variables such as gender, doses, study center, etc. However, the included variables differed across studies, and some trial reports did not report the adjusted covariates. It was therefore not possible to combine studies that all used a common analytic model.

Meta-analyses, or even qualitative syntheses, in the case of high heterogeneity, comparing lower dose (specific) statin plus another lipid modifying drug with higher dose of the same statin as monotherapy, were not conducted when the trial:

- employed two different statin types in combination and monotherapy;
- compared a lower dose of a particular statin in combination therapy with a higher dose of the same statin monotherapy, but both doses met our pre-stated lower or higher dose criteria (see above). For example, atorvastatin 40 mg/day in combination with another lipid lowering drug versus atorvastatin 80 mg/day monotherapy would not be considered in lower statin dose combination versus higher dose monotherapy syntheses, since both atorvastatin doses qualified as higher doses;
- reported only pooled data despite randomization of participants to appropriate lower and higher doses of statins;
- employed randomization to a non-statin lipid lowering drug or placebo as add-on to background statin therapy in which participants were already taking a variety of statins in various doses;
- employed an identical dose of statin in both combination and monotherapy arms; or
- employed a higher dose of statin in the combination arm(s) than monotherapy arm(s).

Potential publication bias was explored graphically through funnel plots for each comparison of interest for which meta-analyses were conducted. Although other explanations exist, an asymmetric funnel plot suggests the possibility of bias. In addition, the degree of funnel plot asymmetry was measured by the intercept from regression of standard normal deviates against precision – the Egger‘s regression test.85 A two-tailed p-value above 0.1 was considered to be significant for lateral asymmetry of the funnel plot.

We planned to:

- present forest plots for important outcomes regardless of heterogeneity as long as there were at least two trials contributing to the synthesis – namely, all-cause mortality, vascular death, participants attaining ATP-III LDL-c targets, LDL-c and serious adverse events;
- conduct meta-analysis and report pooled estimate only when I2 was not greater than 50 percent;
- present funnel plots as long as there were at least six included studies in an analysis; and
- perform Egger’s regression test if there were more than 10 studies included in an analysis.