# 1 Introduction

## Background

Over 28 million Americans have some form of cardiovascular disease (CVD) and these conditions cause more deaths than cancer, diabetes, accidents and chronic lung diseases combined.1 An American dies every 36 seconds as a result of CVD, amounting to 2,400 deaths per day.1

CVD includes coronary heart disease (CHD), heart failure (HF) and stroke. The Framingham Heart Study, an ongoing longitudinal study of CVD and its risk factors, suggests that the lifetime risk of developing disease for those well at age 50 is 51.7 percent for men and 39.2 percent for women.8 Direct medical expenditures and lost productivity as a result of these conditions result in an estimated cost of $431.8 billion in the United States in the year 2007.^9^

Experimental evidence linking cholesterol and vascular disease existed as early as the beginning of the 20th century. In 1913 Nikolai Anitschkow, a Russian experimental pathologist demonstrated that feeding rabbits a diet rich in cholesterol resulted in vascular lesions with the same pathology as those which were known to occur in human atherosclerosis.10

Ancel Keys, working at the University of Minnesota, performed one of the earliest epidemiologic studies correlating cholesterol levels with the risk of death from CHD in the Seven Countries study.11–13 This ecologic correlation data analysis demonstrated a relationship between dietary cholesterol intake, serum cholesterol levels and the CHD death rate of seven populations chosen to represent a range of serum cholesterol.

The American Heart Association accepted that cholesterol was causally linked to CHD as early as 1961, and recommended that people at high risk be advised to modify their diets.10 The first large trial demonstrating a reduction in cardiac endpoints by lowering cholesterol levels was the Coronary Primary Prevention trial, funded by the National Institutes of Health (NIH) and published in 1984.^14^ Subsequently the National Cholesterol Education Program (NCEP) was established, with its first report published in 1988.^15^ The era of potent lipid lowering therapies was ushered in by the 4S Trial, which demonstrated a 42 percent reduction in CHD mortality and a reduction in all cause mortality following treatment with simvastatin. The NCEP guidelines have been updated, with the most recent full report published in 2002 as the Adult Treatment Panel III (ATP III).16

An understanding of the biology underlying vascular disease has paralleled the development of therapeutic options and guidelines. Atherosclerosis is a pathologic process involving injury to vessel walls with subsequent accumulation of lipids, proteins and inflammatory cells within the wall. Impairment of blood flow due to blockage of the vessel, and promotion of thrombosis or embolization of material into smaller blood vessels result in impaired function or death of tissues.

Cholesterol is transported in the blood as particles combining lipids and proteins called lipoproteins. Low density lipoprotein cholesterol (LDL-c) level in the serum is positively correlated with the development of atherosclerosis, while the levels of high density lipoprotein cholesterol (HDL-c) show an inverse relationship with the atherosclerotic process. The levels of HDL-c are affected by a number of other risk factors including diabetes, obesity and smoking. Guidelines have not identified a level of HDL-c as a goal for therapy, although ATP III does encourage therapies to elevate HDL-c as part of the management strategy.16 Additionally, elevated serum triglycerides are atherogenic and associated with increased risk for CHD. Therefore, lifestyle modification is recommended for first line therapy in individuals with elevated triglycerides. The biologic processes and interactions between other lipid fractions and risk factors are complex and beyond the scope of this review.

Trial evidence suggests that lowering of LDL-c results in a reduction in CHD and, recently, rates of ischemic stroke.17,18 Due to the consistent and robust association of higher LDL-c levels with disease across experimental and epidemiologic studies, therapeutic strategies have focused on LDL-c reduction as the primary goal. The ATP III report established three risk strata for CHD, with upper LDL-c cut-off points for the initiation of treatment and therapeutic LDL-c targets. The highest risk individuals were defined as those with established CHD or CHD risk equivalents (i.e. diabetes, clinical atherosclerotic disease in other vascular beds, or multiple (2 or more) risk factors resulting in a CHD ten year risk of more than 20 percent). This stratification expanded the population for whom lipid lowering therapy was recommended.

Following the 2002 publication of the NCEP ATP III guidelines, five major trials were published, resulting in a revision in 2004.^19^ These additions to the evidence base led to the inclusion of diabetes as a CHD equivalent risk and reinforced the benefits of lowering LDL-c in older individuals. In addition, for very high risk individuals, more aggressive targets were felt to be a therapeutic option. The previous target of LDL-c below 100 mg/dL was supplemented with an optional goal of LDL-c below 70 mg/dL in very high risk populations who already have baseline LDL-c below 100 mg/dL. Very high risk individuals were defined as those with acute coronary syndromes, multiple major risk factors (especially diabetes and smoking), severe and poorly controlled risk factors, and multiple risk factors for metabolic syndrome.19 High risk patients continued to be defined as in the 2002 ATP III. While the optional target of LDL-c below 70 mg/dL was supported by two of the reviewed trials,20,21 further trial confirmation was sought prior to considering this to be definitive. Finally, ATP III suggests that individuals without established disease or multiple risk factors but with an LDL-c above 190 mg/dL should be treated to a target LDL-c of 160 mg/dL. This population may also be considered to be in need of intensive lipid lowering therapy if the initial LDL-c is very high.

Cholesterol is a structural component of cellular membranes, and is a precursor of steroid hormones and bile acids. Plasma cholesterol levels are influenced by production in the liver as well as absorption of ingested fats. Hepatic synthesis of cholesterol begins with 2-carbon acetyl-CoA moities which are condensed to hydroxymethylglutaryl-CoA (HMG-CoA) by HMG-CoA synthase. The next step in this metabolic pathway, the conversion of HMG-CoA to mevalonate by HMG-CoA reductase, has been the chief pharmaceutical target. Dietary cholesterol reaches the liver after absorption in the intestine as chylomicrons containing triglycerides and cholesterol. The triglycerides are metabolized to fatty acids that are taken up by peripheral tissue, leaving the cholesterol rich particles to be absorbed by the liver. Bile acids, which are critical for absorption of dietary fat and fat soluble vitamins, are produced in the liver and excreted with free cholesterol into the intestine. Approximately 90 percent of the excreted bile salts are reabsorbed during digestion. Cholesterol is actively absorbed from the intestine by Niemann-Pick C1-Like 1 protein (NPC1L1), localized in jejunal enterocytes.

A number of medications are available for use as lipid lowering therapy (Table 1). These agents differ in mechanism of action and pharmacokinetic properties (Appendix C).

Table 1

Drugs included in the review

Drug | Trade name | Dosage Form
HMG-CoA reductase inhibitors (Statins) inhibit conversion of 3-hydroxy-3-methylglutaryl-coenzyme A (HMG-CoA) to mevalonate, an early step in the cholesterol biosynthetic pathway
Atorvastatin Calcium | Lipitor^®^ | 10, 20, 40, 80 mg tablets
Fluvastatin sodium or Fluvastatin sodium Extended-Release | Lescol^®^ or Lescol^®^ XL | 20, 40 mg Lescol^®^ capsules and 80 mg Lescol^®^ XL tablets
Lovastatin | ALTOCOR^™^ Extended release | 10, 20, 40, 60 mg tablets
Pravastatin sodium | PRAVACHOL^®^ | 10, 20, 40, 80 mg tablets
Rosuvastatin calcium | CRESTOR^®^ | 5, 10, 20, 40 mg tablets
Simvastatin | ZOCOR^®^ | 5, 10, 20, 40, 80 mg tablets
Ezetimibe selective inhibitor of intestinal cholesterol and related phytosterol absorption by the Niemann-Pick C1-Like 1 (NPC1L1) sterol transporter in the brush border of the small intestine
Ezetimibe | Zetia^®^ | 10 mg tablets
Ezetimibe/Simvastatin | Vytorin^™^ | 10/10, 10/20, 10/40, 10/80 mg ezitimibe/mg Simvastatin
Fibrates
Fenofibrate | TRICOR^®^ | 54, 160 mg tablets
Micronized fenofibrate | Lofibra^®^ | 134, 200 mg tablets
Gemfibrozil | LOPID^®^ | 600 mg tablets
Niacin
Niacin (NIR) | Niacor^®^ | 500 mg tablets
Niacin extended-release (NER) | NIASPAN^®^ | 500, 750, 1000 mg
Niacin extended-release/lovastatin | Advicor^®^ | 500/20, 750/20, 1000/20 mg niacin/mg Lovastatin
Bile acid sequestrants - Strong acid ion exchange resins that are not bioabsorbed, to remove bile acids from hepatic re-circulation
Cholestyramine | Cholestyramine | 9 g/dose (packet or scoop) mixed with liquid
Colestipol | Cholestid^®^ | 5 g/scoop granules or 1 g tablets
Colesevelam | Welchol^®^ | 625 mg tablets
Omega-3 fatty acids
Omega-3-acid ethyl esters | OMACOR^®^ | 1 g capsules (900 mg ethyl esters of omega-3 fatty acids) ~ 465 mg EPA, ~ 375 mg DHA

Abbreviations: ~ = approximately, DHA = docosahexaenoic acid, EPA = eicosapentaenoic acid, g = gram, mg = milligram

The most widely prescribed agents are the 3-hydroxy-3-methylglutaryl coenzyme A (HMG-CoA) reductase inhibitors commonly known as statins. These agents are structural analogues of HMG-CoA, the rate limiting enzyme for cholesterol synthesis in the liver, and competitively bind to it. Statins also reduce plasma cholesterol by upregulating the LDL-c receptor, that leads to increased uptake of LDL-c from the blood. A number of other actions have been noted experimentally including suppression of inflammatory molecules, stimulation of endothelial nitric oxide (eNOS), and inhibition of smooth muscle proliferation and reactive oxygen species. These mechanisms may have a role in the reduction of clinical events, though some debate remains. The older statins (mevastatin, lovastatin, pravastatin, and simvastatin ) are fungal metabolites, whereas the newer ones are synthetic (fluvastatin, atorvastatin, and rosuvastatin).

In contrast with statins, fibrates do not influence lipid synthesis but rather reduce the levels of fatty acids in the blood by facilitating oxidation of these molecules. Fibrates are synthetic ligands for hormone activated nuclear receptors, chiefly peroxisome proliferator-activated receptor α (PPARα).22 PPARα binding results in alteration of the transcription rate of target genes related to lipid metabolism.23 Fibrates reduce triglyceride levels by 30–50 percent and may have beneficial effects on HDL-c and LDL-c levels, depending on the baseline phenotype.23 As statins do not have a significant impact on triglyceride levels, use of these agents has been an option in populations with hypertriglyceridemia or mixed dyslipidemia, in place of or in addition to statins.24 Individuals with diabetes mellitus or metabolic syndrome form important high risk groups for whom fibrate therapy may be considered.24 Two fibrates, gemifibrozil and fenofibrate, are available for use in the U.S.

Ezetimibe is an agent that inhibits intestinal absorption by acting on the sterol transporter NPC1L1.^2^ Thus combination therapy using a statin plus ezetimibe has the potential to influence both the biosynthetic pathway for cholesterol synthesis and absorption, resulting in a greater reduction in LDL-c levels than with either agent alone. Ezetimibe monotherapy results in a LDL-c reduction of approximately 18 percent, along with a reduction in triglycerides and elevation in HDL-c.25

Niacin (nicotinic acid) reduces LDL-c and increases HDL-c via a mechanism yet to be fully elucidated. Niacin is suspected to be involved in the metabolism of apolipoproteins, stimulating production of Apo A-I and Apo A-II, and possibly decreasing their turnover. It also decreases synthesis of LDL-c and VLDL-c, without affecting fecal excretion of fats and bile acids.26,27 Niacin was first introduced in 1954 and is available in immediate release, slow release and extended release forms. However the high prevalence of side effects, chiefly flushing and rash which may occur in up to 60 percent of individuals, has limited usage.28

Bile acid sequestrants (BAS) bind bile acids in the bowel. The bound bile acids are subsequently excreted in the feces, thereby preventing reabsorption and depleting the intrahepatic pool of bile acids. BAS are not absorbed in the intestine and thus do not have systemic side effects. These agents have been available for over thirty years, with clinical benefit demonstrated in the Lipid Research Clinics Coronary Primary Prevention Trial.14 This trial demonstrated a reduction in CAD (coronary heart disease) of approximately 19 percent in dyslipidemic males with cholestyramine used as monotherapy. Drawbacks of these agents include gastrointestinal side effects, especially constipation, the need for frequent dosing, and the potential to interfere with absorption of other drugs and essential nutrients such as some vitamins.29

Omega-3 fatty acids have been postulated to have a number of beneficial effects in individuals at risk for vascular disease, including antithrombotic and blood pressure lowering effects. They are considered to be lipid modifying agents due to a reduction in triglycerides, particularly postprandially.30–33 Omega-3 fatty acids come in two forms: the fish oil derived long chain fatty acids, eicosapentaenoic (EPA), docosapentaenoic (DPA) and docosahexaenoic (DHA), and the plant oil derived alpha linolenic acid (ALA). Based on a review of the available epidemiologic and trial data the American Heart Association (AHA) nutrition committee has recommended an intake of one gram of EPA+DHA per day for individuals with documented CHD and two to four grams per day for those needing to lower triglycerides.34

A large number of Americans fall into populations requiring lipid modifying therapy. The populations have been well defined by the ATP III guidelines and recent modifications have served to increase both the number of individuals falling into groups for whom therapy is recommended as well as increasing the intensity of treatment recommended to reach lower targets. For this systematic review, populations requiring intensive lipid lowering are considered to be those with a 10 year risk of CHD greater than 20 percent, or baseline LDL cholesterol of at least 190mg/dL. Lipid lowering in these populations is likely to require treatment modifications in order to achieve LDL-c targets and maximal clinical benefit. Therapeutic options for individuals requiring intensive lowering of cholesterol include an increased dose of a statin medication or the use of a statin in combination with a lipid modifying agent of another class. The purpose of this review is to compare the benefits and risks of these two options.

## Scope and Key Questions

Normal LDL-c values range from 50 mg/dL to 70 mg/dL in native hunter-gatherers, newborn infants and wild primates, none of whom develop atherosclerosis.35 Lowering of LDL-c has been shown to reduce major coronary and cerebrovascular events.17,18,36 Additionally, higher serum HDL-c levels have been associated with reduced CHD risk.37,38 Early arterial atherosclerotic changes have also been shown to be positively correlated with cardiovascular events.39,40

Lipid modifying therapy with statins and other non-statin medications aims to reduce these major clinical events and associated mortality primarily by effecting favorable changes in LDL-c, HDL-c and TC:HDL-c ratio.

LDL-c reduction is the primary intermediate goal.41,42 The Executive Summary of the Third Report of the NCEP Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (ATP III) indicates that LDL-c is the primary target of lipid modifying therapy.43

Only one third of all patients achieve their LDL-c goals, and proportionally even fewer of those with with established CHD.44 Alternatives for patients who remain dyslipidemic despite ongoing statin therapy include dose titration, combination therapy or prescribing a more efficacious statin. Increasing statin dose or potency, potentially increases the frequency of important adverse events such as rhabdomyolysis and liver damage. Combining statin therapy with another lipid-modifying agent could be an alternative, relative safety and efficacy of which remain unclear.45 As noted in the wording of the key questions below, this review does not address the addition of a second agent in populations not at target in spite of maximal statin therapy.

The analytic framework (Figure 1) depicts the approach taken to address the key questions, and the specifics we explored. The framework reflects the relative importance of outcomes queried in key questions and their linkages based on extant epidemiologic evidence.

Figure 1

Analytic framework

Abbreviations: ACS = acute coronary syndrome, ATPIII = Adult Treatment Panel III (of the NCEP), DM = diabetes mellitus, HDL-c = high density lipoprotein cholesterol, LDL-c = low density lipoprotein cholesterol, non-HDL-c – non-high density lipoprotein-c, Q = question, TG = triglycerides, TIA = transient ischemic attack

Key Question 1. For patients who require intensive lipid-modifying therapy, what are the comparative long-term benefits, and rates of serious adverse events of coadministration of different lipid-modifying agents (i.e. a statin plus another lipid-modifying agent) compared with higher dose statin monotherapy?

Key Question 2. Do these regimens differ in reaching LDL-targets (or other surrogate markers), short-term side effects, tolerability, and/or adherence?

Key Question 3. Compared with higher-dose statins, and to one another, do combination regimens differ in benefits and harms within subgroups of patients