# 5 Conclusions

Statin therapy has been an invaluable tool in the prevention of vascular disease, with robust evidence to support benefit for important clinical outcomes. The trend toward more stringent targets and identification of coronary heart disease risk equivalents is increasing the number of Americans being identified as potentially benefitting from lipid modifying therapies, and combination therapy is likely to increase in order to achieve targets expanded populations of high risk individuals.

In summary, the available clinical trial evidence supporting the use of combination therapies over higher dose statin therapy is insufficient to guide clinical decisions. The long term clinical benefits and risks of combination therapies have yet to be demonstrated. There are some instances, such as failure to reach targets in spite of maximal statin therapy, and populations with elevated triglycerides who need to achieve secondary goals, in which clinicians may choose combinations pending definitive evidence.

It is improbable that a single therapeutic strategy will be optimal for all individuals, so future research should be targeted to specific clinical and lipid profiles. A number of questions remain as to the optimal strategies for addressing efficacy, safety and adherence for lipid modification in those requiring intensive therapy. Long term trials examining clinical outcomes are required to resolve these issues.