# Appendix I References

1 Minino AM, Heron MP, Smith BL. (2006). Deaths: preliminary data for 2004. Natl Vital Stat Rep.
2 Garcia-Calvo M, Lisnock J, Bull HG, et al. (2005). The target of ezetimibe is Niemann-Pick C1-Like 1 (NPC1L1). Proc Natl Acad Sci U S A.
3 Vickers AJ. (2001). The use of percentage change from baseline as an outcome in a controlled trial is statistically inefficient: a simulation study. BMC Med Res Methodol.
4 Bucher HC, Guyatt GH, Griffith LE, et al. (1997). The results of direct and indirect treatment comparisons in meta-analysis of randomized controlled trials. J Clin Epidemiol.
5 Lexchin J, Bero LA, Djulbegovic B, et al. (2003). Pharmaceutical industry sponsorship and research outcome and quality: systematic review. BMJ.
6 Merrick C. (1995). Video views. J Orthop Sports Phys Ther.
7 Bero L, Oostvogel F, Bacchetti P, et al. (2007). Factors associated with findings of published trials of drug-drug comparisons: why some statins appear more efficacious than others. PLoS Med.
8 Lloyd-Jones DM, Leip EP, Larson MG, et al. (2006). Prediction of lifetime risk for cardiovascular disease by risk factor burden at 50 years of age. Circulation.
9 Mackay J, Mensah G. (2004). The Atlas of Heart Disease and Stroke.
10 Steinberg D. (2004). Thematic review series: the pathogenesis of atherosclerosis. An interpretive history of the cholesterol controversy: part I. J Lipid Res.
11 Keys A, Aravanis C, Blackburn HW, et al. (1966). Epidemiological studies related to coronary heart disease: characteristics of men aged 40–59 in seven countries. Acta Med Scand Suppl.
12 Keys A. (1997). Coronary heart disease in seven countries. 1970. Nutrition.
13 Keys A. (1980). Seven countries: A multivariate analysis of death and coronary heart disease.
14 Anonymous. (1984). The Lipid Research Clinics Coronary Primary Prevention Trial results. II. The relationship of reduction in incidence of coronary heart disease to cholesterol lowering. JAMA.
15 Anonymous. (1988). Report of the National Cholesterol Education Program Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults. The Expert Panel. Arch Intern Med.
16 National Cholestrol Education Program. (2002). Detection evaluation and treatment of high blood cholesterol in adults (Adult treatment panel 3) 02-5215.
17 Baigent C, Keech A, Kearney PM, et al. (2005). Efficacy and safety of cholesterol-lowering treatment: prospective meta-analysis of data from 90,056 participants in 14 randomised trials of statins [erratum appears in Lancet 2005 Oct 15–21;366(9494):1358]. Lancet.
18 Amarenco P, Bogousslavsky J, Callahan III A, et al. (2006). High-dose atorvastatin after stroke or transient ischemic attack [see comment]. N Engl J Med.
19 Grundy SM, Cleeman JI, Bairey Merz CN, et al. (2004). Implications of recent clinical trials for the National Cholesterol Education Program Adult Treatment Panel III guidelines. Circulation.
20 Anonymous. (2002). MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial. Lancet.
21 Cannon CP, Braunwald E, McCabe CH, et al. (2004). Intensive versus moderate lipid lowering with statins after acute coronary syndromes [see comment]. N Engl J Med.
22 Staels B, Dallongeville J, Auwerx J, et al. (1998). Mechanism of action of fibrates on lipid and lipoprotein metabolism. Circulation.
23 Barter PJ, Rye KA. (2008). Is there a role for fibrates in the management of dyslipidemia in the metabolic syndrome?. Arterioscler Thromb Vasc Biol.
24 Goldenberg I, Benderly M, Goldbourt U. (2008). Update on the use of fibrates: focus on bezafibrate. Vasc Health Risk Manag.
25 Knopp RH, Dujovne CA, Le BA, et al. (2003). Evaluation of the efficacy, safety, and tolerability of ezetimibe in primary hypercholesterolaemia: a pooled analysis from two controlled phase III clinical studies. Int J Clin Pract.
26 Shepherd J, Packard CJ, Patsch JR, et al. (1979). Effects of nicotinic acid therapy on plasma high density lipoprotein subfraction distribution and composition and on apolipoprotein A metabolism. J Clin Invest.
27 Sakai T, Kamanna VS, Kashyap ML. (2001). Niacin, but not gemfibrozil, selectively increases LP-AI, a cardioprotective subfraction of HDL, in patients with low HDL cholesterol. Arterioscler Thromb Vasc Biol.
28 Birjmohun RS, Hutten BA, Kastelein JJ, et al. (2004). Increasing HDL cholesterol with extended-release nicotinic acid: from promise to practice [review] [33 refs]. Neth J Med.
29 Insull J. (2006). Clinical utility of bile acid sequestrants in the treatment of dyslipidemia: A scientific review. South Med J.
30 Anonymous. (1993). Physician's Desk Reference.
31 Anonymous. (1990). American Hospital Formulary Service (AHFS) Drug Information.
32 US Food and Drug AdministrationCentre for Drug Evaluation and Research. (1992). Approved Drug Products with Therapeutic Equivalence Evaluation (Orange Book).
33 Harris WS. (1997). N-3 fatty acids and serum lipoproteins: human studies. Am J Clin Nutr.
34 Kris-Etherton PM, Harris WS, Appel LJ. (2003). Omega-3 fatty acids and cardiovascular disease: new recommendations from the American Heart Association. Arterioscler Thromb Vasc Biol.
35 O'Keefe Jr JH, Cordain L, Harris WH, et al. (2004). Optimal low-density lipoprotein is 50 to 70 mg/dl: lower is better and physiologically normal. J Am Coll Cardiol.
36 Grundy SM, Cleeman JI, Merz CN, et al. (2004). Implications of recent clinical trials for the National Cholesterol Education Program Adult Treatment Panel III guidelines. Circulation.
37 Manninen V, Elo MO, Frick MH, et al. (1988). Lipid alterations and decline in the incidence of coronary heart disease in the Helsinki Heart Study. JAMA.
38 Rubins HB, Robins SJ, Collins D, et al. (1999). Gemfibrozil for the secondary prevention of coronary heart disease in men with low levels of high-density lipoprotein cholesterol. Veterans Affairs High-Density Lipoprotein Cholesterol Intervention Trial Study Group. N Engl J Med.
39 O'Leary DH, Polak JF, Kronmal RA, et al. (1999). Carotid-artery intima and media thickness as a risk factor for myocardial infarction and stroke in older adults. Cardiovascular Health Study Collaborative Research Group. N Engl J Med.
40 Amarenco P, Labreuche J, Lavallee P, et al. (2004). Statins in stroke prevention and carotid atherosclerosis: systematic review and up-to-date meta-analysis [review] [62 refs]. Stroke.
41 Brown BG, Taylor AJ. (2008). Does ENHANCE diminish confidence in lowering LDL or in ezetimibe?. N Engl J Med.
42 Kastelein JJ, Akdim F, Stroes ES, et al. (2008). Simvastatin with or without ezetimibe in familial hypercholesterolemia. N Engl J Med.
43 Anonymous. (2002). Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circulation.
44 American Heart Association. Heart Disease and Stroke Statistics — 2008 Update.
45 Schuster H. (2004). Improving lipid management--to titrate, combine or switch [review] [55 refs]. Int J Clin Pract.
46 Ballantyne CM, Blazing MA, King TR, et al. (2004). Efficacy and safety of ezetimibe co-administered with simvastatin compared with atorvastatin in adults with hypercholesterolemia. Am J Cardiol.
47 Feldman T, Koren M, Insull W, et al. (2004). Treatment of high-risk patients with ezetimibe plus simvastatin co-administration versus simvastatin alone to attain National Cholesterol Education Program Adult Treatment Panel III low-density lipoprotein cholesterol goals. Am J Cardiol.
48 Goldberg AC, Sapre A, Liu J, et al. (2004). Efficacy and safety of ezetimibe coadministered with simvastatin in patients with primary hypercholesterolemia: a randomized, double-blind, placebo-controlled trial [see comment]. Mayo Clin Proc.
49 Bays HE, Dujovne CA, McGovern ME, et al. (2003). Comparison of once-daily, niacin extended-release/lovastatin with standard doses of atorvastatin and simvastatin (the ADvicor Versus Other Cholesterol-Modulating Agents Trial Evaluation [ADVOCATE]). Am J Cardiol.
50 Athyros VG, Papageorgiou AA, Athyrou VV, et al. (2002). Atorvastatin versus four statin-fibrate combinations in patients with familial combined hyperlipidaemia. J Cardiovasc Risk.
51 Brown BG, Zhao XQ, Chait A, et al. (2001). Simvastatin and niacin, antioxidant vitamins, or the combination for the prevention of coronary disease [see comment][summary for patients in Curr Cardiol Rep 2002 Nov;4(6):486; PMID: 12379170]. N Engl J Med.
52 Sprecher DL, Abrams J, Allen JW, et al. (1994). Low-dose combined therapy with fluvastatin and cholestyramine in hyperlipidemic patients.[see comment]. Ann Intern Med.
53 Robinson M, Palmer S, Sculpher M, et al. (2001). Cost-effectiveness of alternative strategies for the initial medical management of non-ST elevation acute coronary syndrome: systematic review and decision-analytical modelling [review] [111 refs]. Health Technol Assess.
54 Bard JM, Parra HJ, Luc G, et al. (1991). Lipoprotein particle analysis comparing simvastatin and fenofibrate. Atherosclerosis.
55 Plosker GL, McTavish D. (1995). Simvastatin. A reappraisal of its pharmacology and therapeutic efficacy in hypercholesterolaemia [review] [239 refs]. Drugs.
56 Molgaard J, Lundh BL, von SH, et al. (1991). Long-term efficacy and safety of simvastatin alone and in combination therapy in treatment of hypercholesterolaemia. Atherosclerosis.
57 Catapano A, Brady WE, King TR, et al. (2005). Lipid altering-efficacy of ezetimibe co-administered with simvastatin compared with rosuvastatin: a meta-analysis of pooled data from 14 clinical trials. Curr Med Res Opin.
58 Perez-Jimenez F. (2005). International conference on the healthy effect of virgin olive oil [review] [25 refs]. Eur J Clin Invest.
59 Valles F, Anguita M, Anglada J, et al. (1991). A multicenter double-blind study comparing lovastatin and gemfibrozil in the treatment of primary hypercholesterolemia. Atherosclerosis.
60 Hochholzer W, Trenk D, Frundi D, et al. (2005). Time dependence of platelet inhibition after a 600-mg loading dose of clopidogrel in a large, unselected cohort of candidates for percutaneous coronary intervention [see comment]. Circulation.
61 Komninou D, Ayonote A, Richie JP, et al. (2003). Insulin resistance and its contribution to colon carcinogenesis [review] [107 refs]. Exp Biol Med (Maywood ).
62 Grundy SM, Cleeman JI, Merz CN, et al. (2004). Implications of recent clinical trials for the National Cholesterol Education Program Adult Treatment Panel III guidelines [review] [45 refs]. Arterioscler Thromb Vasc Biol.
63 Strandberg TE, Pitkala KH. (2007). Frailty in elderly people. Lancet.
64 Jasinska M, Owczarek J, Orszulak-Michalak D. (2007). Statins: a new insight into their mechanisms of action and consequent pleiotropic effects. Pharmacol Rep.
65 Liao JK, Laufs U. (2005). Pleiotropic effects of statins [review] [180 refs]. Annu Rev Pharmacol Toxicol.
66 Vickers AJ. (2001). The use of percentage change from baseline as an outcome in a controlled trial is statistically inefficient: a simulation study. BMC Med Res Methodol.
67 Elbourne DR, Altman DG, Higgins JP, et al. (2002). Meta-analyses involving cross-over trials: methodological issues. Int J Epidemiol.
68 Bairaktari ET, Seferiadis KI, Elisaf MS. (2005). Evaluation of methods for the measurement of low-density lipoprotein cholesterol. J Cardiovasc Pharmacol Ther.
69 Miller WG, Waymack PP, Anderson FP, et al. (2002). Performance of four homogeneous direct methods for LDL-cholesterol. Clin Chem.
70 Working Group on Lipoprotein Measurement. (1995). Recommendations on lipoprotein measurement 95–3044.
71 Bachorik PS, Ross JW. (1995). National Cholesterol Education Program recommendations for measurement of low-density lipoprotein cholesterol: executive summary. The National Cholesterol Education Program Working Group on Lipoprotein Measurement. Clin Chem.
72 Warnick GR, Myers GL, Cooper GR, et al. (2002). Impact of the third cholesterol report from the adult treatment panel of the national cholesterol education program on the clinical laboratory. Clin Chem.
73 Kratz A, Lewandrowski KB. (1998). Case records of the Massachusetts General Hospital. Weekly clinicopathological exercises. Normal reference laboratory values. N Engl J Med.
74 Jadad AR, Moore RA, Carroll D, et al. (1996). Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials.
75 Schulz KF, Chalmers I, Hayes RJ, et al. (1995). Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA.
76 Downs SH, Black N. (1998). The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health.
77 Cochrane Handbook for Systematic Reviews of Interventions [updated September 2008].
78 Atkins D, Best D, Briss PA, et al. (2004). Grading quality of evidence and strength of recommendations. BMJ.
79 Brozek J, Oxman A, Schünemann H. (2008). GRADEpro [software application].
80 Greenland S. (1994). Invited commentary: a critical look at some popular meta-analytic methods. Am J Epidemiol.
81 Lau J, Ioannidis JP, Schmid CH. (1998). Summing up evidence: one answer is not always enough. Lancet.
82 Shapiro S. (1994). Meta-analysis/Shmeta-analysis. Am J Epidemiol.
83 Higgins JP, Thompson SG. (2002). Quantifying heterogeneity in a meta-analysis. Stat Med.
84 DerSimonian R, Laird N. (1986). Meta-analysis in clinical trials. Control Clin Trials.
85 Egger M, Davey SG, Schneider M, et al. (1997). Bias in meta-analysis detected by a simple, graphical test. BMJ.
86 Turk TR, Voropaeva E, Kohnle M, et al. (2008). Ezetimibe treatment in hypercholesterolemic kidney transplant patients is safe and effective and reduces the decline of renal allograft function: a pilot study. Nephrol Dial Transplant.
87 van Dam M, Kastelein J. (2001). Efficacy and tolerability of fluvastatin in a titration dosage regimen in hyperlipidaemic patients: Results of a multicentre phase IV study. Clin Drug Investig.
88 Ojala JP, Helve E, Karjalainen K, et al. (1990). Long-term maintenance of therapeutic response to lovastatin in patients with familial and non-familial hypercholesterolemia: a 3-year follow-up. Atheroscler Suppl.
89 Mol MJ, Stuyt PM, Demacker PN, et al. (1990). The effects of simvastatin on serum lipoproteins in severe hypercholesterolaemia. Neth J Med.
90 Tasaki H, Miyamoto M, Kubara T, et al. (2006). Cross-over trial of intensive monotherapy with atorvastatin and combined therapy with atorvastatin and colestimide for Japanese familial hypercholesterolemia. Circ J.
91 Koh KK, Quon MJ, Han SH, et al. (2005). Additive beneficial effects of fenofibrate combined with atorvastatin in the treatment of combined hyperlipidemia. J Am Coll Cardiol.
92 Vega GL, Ma PT, Cater NB, et al. (2003). Effects of adding fenofibrate (200 mg/day) to simvastatin (10 mg/day) in patients with combined hyperlipidemia and metabolic syndrome. Am J Cardiol.
93 Balestrieri GP, Maffi V, Sleiman I, et al. (1996). Fish oil supplementation in patients with heterozygous familial hypercholesterolemia. Recenti Prog Med.
94 Smit JW, Van Erpecum KJ, Portincasa P, et al. (1995). Effects of simvastatin and cholestyramine on bile lipid composition and gall bladder motility in patients with hypercholesterolaemia. Gut.
95 Hansen JB, Lyngmo V, Svensson B, et al. (1993). Inhibition of exercise-induced shortening of bleeding time by fish oil in familial hypercholesterolemia (type IIa). Arterioscler Thromb.
96 Morgan TO, Anderson A, Morgan O, et al. (1995). Effect of pravastatin, cholestyramine or their combination in the treatment of hypercholesterolaemia in elderly hypertensive patients. Clin Drug Investig.
97 McKenney JM, Swearingen D, Di SM, et al. (2006). Study of the pharmacokinetic interaction between simvastatin and prescription omega-3-acid ethyl esters. J Clin Pharmacol.
98 Anonymous. A phase-III double-blind efficacy and safety study of ezetimibe (sch 58235) 10 mg in addition to simvastatin compared with placebo in subjects with primary hypercholesterolemia [extension phase]-[FDA − Eze + simva (P02156 )].
99 Anonymous. Efficacy and safety of ezetimibe coadministered with simvastatin in patients with primary hypercholesterolemia: a randomized, double-blind, placebo-controlled trial.[extension phase]-[FDA − Eze + simv (P005x)].
100 Anonymous. A phase II study to determine the safety and efficacy of Colesevelam in combination with HGG-CoA reductase inhibitors: Atorvastatin- FDA GTC-48–204.
101 Anonymous. A phase II efficacy and safety study of ezetimibe (SCH 58235) 10 mg in addition to Simvastatin in therapy of homozygous familial hypercholesterolemia- FDA- P01030.
102 Anonymous. A phase III double-blind efficacy and safety study of ezetimibe (SCH 58235) 10 mg in addition to Pravastatin compared with placebo in subjects with primary hypercholesterolemia- FDA P00691.
103 Anonymous. A phase III double-blind efficacy and safety study of ezetimibe (SCH 58235) 10 mg in addition to Lovastatin compared with placebo in subjects with primary hypercholesterolemia- FDA P00679.
104 Anonymous. Evaluation of the Safety and Efficacy of Advicor (a combination tablet of niacin extended-release/lovastatin immediate-release): A Dose Response Study -[FDA-Advicor (MA-14)].
105 Anonymous. Evaluation of the Safety and Efficacy of Advicor (a combination tablet of niacin extended-release/lovastatin immediate-release): A Dose Ranging Study- [FDA-Advicor (M-06)].
106 Kosoglou T, Meyer I, Veltri EP, et al. (2002). Pharmacodynamic interaction between the new selective cholesterol absorption inhibitor ezetimibe and simvastatin. Br J Clin Pharmacol.
107 Chan DC, Watts GF, Mori TA, et al. (2002). Factorial study of the effects of atorvastatin and fish oil on dyslipidaemia in visceral obesity. Eur J Clin Invest.
108 Ito MK, Shabetai R. (1997). Pravastatin alone and in combination with low-dose cholestyramine in patients with primary hypercholesterolemia and coronary artery disease. Am J Cardiol.
109 Berthold HK, Naini A, Di MS, et al. (2006). Effect of ezetimibe and/or simvastatin on coenzyme Q10 levels in plasma: a randomised trial. Drug Saf.
110 Gouni-Berthold I, Berthold HK, Gylling H, et al. (2008). Effects of ezetimibe and/or simvastatin on LDL receptor protein expression and on LDL receptor and HMG-CoA reductase gene expression: a randomized trial in healthy men. Atherosclerosis.
111 Rodney RA, Sugimoto D, Wagman B, et al. (2006). Efficacy and safety of coadministration of ezetimibe and simvastatin in African-American patients with primary hypercholesterolemia. J Natl Med Assoc.
112 Barrios V, Amabile N, Paganelli F, et al. (2005). Lipid-altering efficacy of switching from atorvastatin 10 mg/day to ezetimibe/simvastatin 10/20 mg/day compared to doubling the dose of atorvastatin in hypercholesterolaemic patients with atherosclerosis or coronary heart disease. Int J Clin Pract.
113 Reyderman L, Kosoglou T, Cutler DL, et al. (2005). The effect of fluvastatin on the pharmacokinetics and pharmacodynamics of ezetimibe. Curr Med Res Opin.
114 Farnier M, Volpe M, Massaad R, et al. (2005). Effect of co-administering ezetimibe with on-going simvastatin treatment on LDL-C goal attainment in hypercholesterolemic patients with coronary heart disease. Int J Cardiol.
115 Cruz-Fernandez JM, Bedarida GV, Adgey J, et al. (2005). Efficacy and safety of ezetimibe co-administered with ongoing atorvastatin therapy in achieving low-density lipoprotein goal in patients with hypercholesterolemia and coronary heart disease. Int J Clin Pract.
116 Brohet C, Banai S, Alings AM, et al. (2005). LDL-C goal attainment with the addition of ezetimibe to ongoing simvastatin treatment in coronary heart disease patients with hypercholesterolemia. Curr Med Res Opin.
117 Pearson TA, Denke MA, McBride PE, et al. (2005). A community-based, randomized trial of ezetimibe added to statin therapy to attain NCEP ATP III goals for LDL cholesterol in hypercholesterolemic patients: the ezetimibe add-on to statin for effectiveness (EASE) trial [see comment]. Mayo Clin Proc.
118 Ballantyne CM, Abate N, Yuan Z, et al. (2005). Dose-comparison study of the combination of ezetimibe and simvastatin (Vytorin) versus atorvastatin in patients with hypercholesterolemia: the Vytorin Versus Atorvastatin (VYVA) study. Am Heart J.
119 Geiss HC, Otto C, Hund-Wissner E, et al. (2005). Effects of ezetimibe on plasma lipoproteins in severely hypercholesterolemic patients treated with regular LDL-apheresis and statins. Atherosclerosis.
120 Grundy SM, Vega GL, Yuan Z, et al. (2005). Effectiveness and tolerability of simvastatin plus fenofibrate for combined hyperlipidemia (the SAFARI trial). Am J Cardiol.
121 Gaudiani LM, Lewin A, Meneghini L, et al. (2005). Efficacy and safety of ezetimibe co-administered with simvastatin in thiazolidinedione-treated type 2 diabetic patients. Diabetes Obes Metab.
122 Ballantyne CM, Miller E, Chitra R. (2004). Efficacy and safety of rosuvastatin alone and in combination with cholestyramine in patients with severe hypercholesterolemia: a randomized, open-label, multicenter trial. Clin Ther.
123 Derosa G, Cicero AE, Bertone G, et al. (2004). Comparison of fluvastatin + fenofibrate combination therapy and fluvastatin monotherapy in the treatment of combined hyperlipidemia, type 2 diabetes mellitus, and coronary heart disease: a 12-month, randomized, double-blind, controlled trial. Clin Ther.
124 Kosoglou T, Statkevich P, Yang B, et al. (2004). Pharmacodynamic interaction between ezetimibe and rosuvastatin. Curr Med Res Opin.
125 Durrington PN, Tuomilehto J, Hamann A, et al. (2004). Rosuvastatin and fenofibrate alone and in combination in type 2 diabetes patients with combined hyperlipidaemia. Diabetes Res Clin Pract.
126 Ballantyne CM, Houri J, Notarbartolo A, et al. (2003). Effect of ezetimibe coadministered with atorvastatin in 628 patients with primary hypercholesterolemia: a prospective, randomized, double-blind trial [see comment]. Circulation.
127 Melani L, Mills R, Hassman D, et al. (2003). Efficacy and safety of ezetimibe coadministered with pravastatin in patients with primary hypercholesterolemia: a prospective, randomized, double-blind trial [see comment]. Eur Heart J.
128 Hunninghake DB, McGovern ME, Koren M, et al. (2003). A dose-ranging study of a new, once-daily, dual-component drug product containing niacin extended-release and lovastatin. Clin Cardiol.
129 Kerzner B, Corbelli J, Sharp S, et al. (2003). Efficacy and safety of ezetimibe coadministered with lovastatin in primary hypercholesterolemia. Am J Cardiol.
130 Davidson MH, McGarry T, Bettis R, et al. (2002). Ezetimibe coadministered with simvastatin in patients with primary hypercholesterolemia [see comment]. J Am Coll Cardiol.
131 Gagne C, Bays HE, Weiss SR, et al. (2002). Efficacy and safety of ezetimibe added to ongoing statin therapy for treatment of patients with primary hypercholesterolemia [see comment]. Am J Cardiol.
132 Gagne C, Gaudet D, Bruckert E, et al. (2002). Efficacy and safety of ezetimibe coadministered with atorvastatin or simvastatin in patients with homozygous familial hypercholesterolemia. Circulation.
133 Hunninghake D, Insull W, Toth P, et al. (2001). Coadministration of colesevelam hydrochloride with atorvastatin lowers LDL cholesterol additively. Atherosclerosis.
134 Wiklund O, Angelin B, Bergman M, et al. (1993). Pravastatin and gemfibrozil alone and in combination for the treatment of hypercholesterolemia [see comment]. Am J Med.
135 Ismail F, Corder CN, Epstein S, et al. (1990). Effects of pravastatin and cholestyramine on circulating levels of parathyroid hormone and vitamin D metabolites. Clin Ther.
136 Barbi G, Corder CN, Koren E, et al. (1992). Effect of pravastatin and cholestyramine on triglyceride-rich lipoprotein particles and Lp(a) in patients with type II hypercholesterolemia. Drug Dev Res.
137 Johansson J. (1995). Low-dose combination therapy with colestipol and simvastatin in patients with moderate to severe hypercholesterolaemia. Nutr Metab Cardiovasc Dis.
138 Heber D, Lembertas A, Lu QY, et al. (2001). An analysis of nine proprietary Chinese red yeast rice dietary supplements: implications of variability in chemical profile and contents. J Altern Complement Med.
139 McKenney JM, Jones PH, Bays HE, et al. (2007). Comparative effects on lipid levels of combination therapy with a statin and extended-release niacin or ezetimibe versus a statin alone (the COMPELL study). Atherosclerosis.
140 Blagden MD, Chipperfield R. (2007). Efficacy and safety of ezetimibe co-administered with atorvastatin in untreated patients with primary hypercholesterolaemia and coronary heart disease. Curr Med Res Opin.
141 Yokoyama M, Origasa H, Matsuzaki M, et al. (2007). Effects of eicosapentaenoic acid on major coronary events in hypercholesterolaemic patients (JELIS): a randomised open-label, blinded endpoint analysis [see comment]. Lancet.
142 Ballantyne CM, Weiss R, Moccetti T, et al. (2007). Efficacy and safety of rosuvastatin 40 mg alone or in combination with ezetimibe in patients at high risk of cardiovascular disease (results from the EXPLORER study). Am J Cardiol.
143 Patel JV, Hughes EA. (2006). Efficacy, safety and LDL-C goal attainment of ezetimibe 10 mg-simvastatin 20 mg vs. placebo-simvastatin 20 mg in UK-based adults with coronary heart disease and hypercholesterolaemia. Int J Clin Pract.
144 Goldberg RB, Guyton JR, Mazzone T, et al. (2006). Ezetimibe/simvastatin vs atorvastatin in patients with type 2 diabetes mellitus and hypercholesterolemia: the VYTAL study. Mayo Clin Proc.
145 Muhlestein JB, May HT, Jensen JR, et al. (2006). The reduction of inflammatory biomarkers by statin, fibrate, and combination therapy among diabetic patients with mixed dyslipidemia: the DIACOR (Diabetes and Combined Lipid Therapy Regimen) study. J Am Coll Cardiol.
146 Chenot F, Montant PF, Marcovitch O, et al. (2007). Co-administration of ezetimibe and simvastatin in acute myocardial infarction. Eur J Clin Invest.
147 Ose L, Johnson-Levonas A, Reyes R, et al. (2007). A multi-centre, randomised, double-blind 14-week extension study examining the long-term safety and efficacy profile of the ezetimibe/simvastatin combination tablet. Int J Clin Pract.
148 Stein EA, Ballantyne CM, Windler E, et al. (2008). Efficacy and tolerability of fluvastatin XL 80 mg alone, ezetimibe alone, and the combination of fluvastatin XL 80 mg with ezetimibe in patients with a history of muscle-related side effects with other statins. Am J Cardiol.
149 Reckless JP, Henry P, Pomykaj T, et al. (2008). Lipid-altering efficacy of ezetimibe/simvastatin 10/40 mg compared with doubling the statin dose in patients admitted to the hospital for a recent coronary event: the INFORCE study [see comment]. Int J Clin Pract.
150 Ballantyne CM, Davidson MH, McKenney J, et al. (2008). Comparison of the safety and efficacy of a combination tablet of niacin extended release and simvastatin vs simvastatin monotherapy in patients with increased non-HDL cholesterol (from the SEACOAST I study). Am J Cardiol.
151 Roeters van Lennep HW, Liem AH, Dunselman PH, et al. (2008). The efficacy of statin monotherapy uptitration versus switching to ezetimibe/simvastatin: results of the EASEGO study. Curr Med Res Opin.
152 Avisar I, Brook JG, Wolfovitz E. (2008). Atorvastatin monotherapy vs. combination therapy in the management of patients with combined hyperlipidemia. EUR.
153 Guyton JR, Goldberg RB, Mazzone T, et al. (2008). Lipoprotein and Apolipoprotein Ratios in the VYTAL Trial of Ezetimibe/Simvastatin Compared with Atorvastatin in Type 2 Diabetes. Journal of Clinical Lipidology.
154 Bays HE, Ose L, Fraser N, et al. (2004). A multicenter, randomized, double-blind, placebo-controlled, factorial design study to evaluate the lipid-altering efficacy and safety profile of the ezetimibe/simvastatin tablet compared with ezetimibe and simvastatin monotherapy in patients with primary hypercholesterolemia. Clin Ther.
155 Capuzzi DM, Morgan JM, Weiss RJ, et al. (2003). Beneficial effects of rosuvastatin alone and in combination with extended-release niacin in patients with a combined hyperlipidemia and low high-density lipoprotein cholesterol levels. Am J Cardiol.
156 Stein E, Stender S, Mata P, et al. (2004). Achieving lipoprotein goals in patients at high risk with severe hypercholesterolemia: efficacy and safety of ezetimibe co-administered with atorvastatin. Am Heart J.
157 Piorkowski M, Fischer S, Stellbaum C, et al. (2007). Treatment with ezetimibe plus low-dose atorvastatin compared with higher-dose atorvastatin alone: is sufficient cholesterol-lowering enough to inhibit platelets?. J Am Coll Cardiol.
158 Conard SE, Bays HE, Leiter LA, et al. (2008). Efficacy and Safety of Ezetimibe Added on to Atorvastatin (20 mg) Versus Uptitration of Atorvastatin (to 40 mg) in Hypercholesterolemic Patients at Moderately High Risk for Coronary Heart Disease. Am J Cardiol.
159 Leiter L, Bays H, Conard S, et al. Efficacy and safety of ezetimibe added on to Atorvastatin (40 mg) compared with uptitration of Atorvastatin (to 80 mg) in hypercholesterolemic patients at high risk of coronary heart disease. American Journal of Cardiology Online.
160 Athyros VG, Mikhailidis DP, Papageorgiou AA, et al. (2005). Targeting vascular risk in patients with metabolic syndrome but without diabetes. Metabolism.
161 Athyros VG, Papageorgiou AA, Athyrou VV, et al. (2002). Atorvastatin and micronized fenofibrate alone and in combination in type 2 diabetes with combined hyperlipidemia [see comment]. Diabetes Care.
162 Moore A, Phan BAP, Challender C, et al. (2007). Effects of adding extended-release niacin and colesevelam to statin therapy on lipid levels in subjects with atherosclerotic disease. Journal of Clinical Lipidology.
163 Isaacsohn JL, Bakker-Arkema RG, Fayyad R, et al. (1997). Atorvastatin, a new HMG-CoA reductase inhibitor, does not affect glucocorticoid hormones in patients with hypercholesterolemia. J Cardiovasc Pharmacol Ther.
164 Heinonen TM, Schrott H, McKenney JM, et al. (1996). Atorvastatin, a new HMG-CoA reductase inhibitor as monotherapy and combined with colestipol. J Cardiovasc Pharmacol Ther.
165 Nordoy A, Hansen JB, Brox J, et al. (2001). Effects of atorvastatin and omega-3 fatty acids on LDL subfractions and postprandial hyperlipemia in patients with combined hyperlipemia. Nutr Metab Cardiovasc Dis.
166 Landray M, Baigent C, Leaper C, et al. (2006). The second United Kingdom Heart and Renal Protection (UK-HARP-II) Study: a randomized controlled study of the biochemical safety and efficacy of adding ezetimibe to simvastatin as initial therapy among patients with CKD. Am J Kidney Dis.
167 Masana L, Mata P, Gagne C, et al. (2005). Long-term safety and, tolerability profiles and lipid-modifying efficacy of ezetimibe coadministered with ongoing simvastatin treatment: a multicenter, randomized, double-blind, placebo-controlled, 48-week extension study. Clin Ther.
168 Shankar PK, Bhat R, Prabhu M, et al. (2007). Efficacy and tolerability of fixed-dose combination of simvastatin plus ezetimibe in patients with primary hypercholesterolemia: Results of a multicentric trial from India. J Clin Lipidol.
169 Dobs, et al. (2003). [Randomised double-blind dosetitration (to target low-density lipoprotein cholesterol) Phase 3 evaluation ... provisional acceptance] [abstract]. J Am Coll Cardiol.
170 Stein EA, Davidson MH, Dujovne CA, et al. (1996). Efficacy and tolerability of low-dose simvastatin and niacin, alone and in combination, in patients with combined hyperlipidemia: a prospective trial. J Cardiovasc Pharmacol Ther.
171 Ballantyne CM, Davidson MH, McKenney J. (2008). Comparison of the safety and efficacy of a combination tablet of niacin extended release and simvastatin with simvastatin 80 mg monotherapy: the SEACOAST II (high-dose) Study). J Clin Lipidology.
172 Knapp HH, Schrott H, Ma P, et al. (2001). Efficacy and safety of combination simvastatin and colesevelam in patients with primary hypercholesterolemia. Am J Med.
173 Simons LA, Simons J, Parfitt A. (1992). Successful management of primary hypercholesterolaemia with simvastatin and low-dose colestipol. Med J Aust.
174 O'Brien RC, Simons LA, Clifton P, et al. (1990). Comparison of simvastatin and cholestyramine in the treatment of primary hypercholesterolaemia [erratum appears in Med J Aust 1991 Feb 18;154(4):296]. Med J Aust.
175 Hong H, Xu ZM, Pang BS, et al. (2004). Effects of simvastatin combined with omega-3 fatty acids on high sensitive C-reactive protein, lipidemia, and fibrinolysis in patients with mixed dyslipidemia. Chin Med Sci J.
176 Durrington PN, Bhatnagar D, Mackness MI, et al. (2001). An omega-3 polyunsaturated fatty acid concentrate administered for one year decreased triglycerides in simvastatin treated patients with coronary heart disease and persisting hypertriglyceridaemia. Heart.
177 Nordoy A, Bonaa KH, Nilsen H, et al. (1998). Effects of Simvastatin and omega-3 fatty acids on plasma lipoproteins and lipid peroxidation in patients with combined hyperlipidaemia. J Intern Med.
178 Davidson MH, ariola-Coad JR, McDonald AM, et al. (1997). Separate and joint effects of marine oil and simvastatin in patients with combined hyperlipidemia. Am J Cardiol.
179 Liu M, Wallmon A, Wallin R, et al. (2003). Effects of stable fish oil and simvastatin on plasma lipoproteins in patients with hyperlipidemia. Nutr Res.
180 Davidson MH, Stein EA, Bays HE, et al. (2007). Efficacy and tolerability of adding prescription omega-3 fatty acids 4 g/d to simvastatin 40 mg/d in hypertriglyceridemic patients: an 8-week, randomized, double-blind, placebo-controlled study. Clin Ther.
181 Kosoglou T, Statkevich P, Meyer I, et al. (2004). Effects of ezetimibe on the pharmacodynamics and pharmacokinetics of lovastatin. Curr Med Res Opin.
182 Insull W, McGovern ME, Schrott H, et al. (2004). Efficacy of extended-release niacin with lovastatin for hypercholesterolemia: assessing all reasonable doses with innovative surface graph analysis. Arch Intern Med.
183 Gardner SF, Schneider EF, Granberry MC, et al. (1996). Combination therapy with low-dose lovastatin and niacin is as effective as higher-dose lovastatin. Pharmacotherapy.
184 Vacek JL, Dittmeier G, Chiarelli T, et al. (1995). Comparison of lovastatin (20 mg) and nicotinic acid (1.2 g) with either drug alone for type II hyperlipoproteinemia. Am J Cardiol.
185 Davidson MH, Toth P, Weiss S, et al. (2001). Low-dose combination therapy with colesevelam hydrochloride and lovastatin effectively decreases low-density lipoprotein cholesterol in patients with primary hypercholesterolemia. Clin Cardiol.
186 Schrott HG, Stein EA, Dujovne CA, et al. (1995). Enhanced low-density lipoprotein cholesterol reduction and cost-effectiveness by low-dose colestipol plus lovastatin combination therapy. Am J Cardiol.
187 Dagli N, Yavuzkir M, Karaca I. (2007). The effects of high dose pravastatin and low dose pravastatin and ezetimibe combination therapy on lipid, glucose metabolism and inflammation. Inflammation.
188 Napoli C, Lepore S, Chiariello P, et al. (1997). Long-term treatment with pravastatin alone and in combination with gemfibrozil in familial type IIB hyperlipoproteinemia or combined hyperlipidemia. J Cardiovasc Pharmacol Ther.
189 O'Keefe Jr JH, Harris WS, Nelson J, et al. (1995). Effects of pravastatin with niacin or magnesium on lipid levels and postprandial lipemia. Am J Cardiol.
190 Eriksson M, Hadell K, Holme I, et al. (1998). Compliance with and efficacy of treatment with pravastatin and cholestyramine: a randomized study on lipid-lowering in primary care. J Intern Med.
191 Pravastatin Multicenter Study Group II. (1993). Comparative efficacy and safety of pravastatin and cholestyramine alone and combined in patients with hypercholesterolemia. Pravastatin Multicenter Study Group II. Arch Intern Med.
192 Smit JW, Jansen GH, De Bruin TW, et al. (1995). Treatment of combined hyperlipidemia with fluvastatin and gemfibrozil, alone or in combination, does not induce muscle damage. Am J Cardiol.
193 Catapano AL, Davidson MH, Ballantyne CM, et al. (2006). Lipid-altering efficacy of the ezetimibe/simvastatin single tablet versus rosuvastatin in hypercholesterolemic patients [see comment]. Curr Med Res Opin.
194 Constance C, Westphal S, Chung N, et al. (2007). Efficacy of ezetimibe/simvastatin 10/20 and 10/40 mg compared with atorvastatin 20 mg in patients with type 2 diabetes mellitus. Diabetes Obes Metab.
195 Shah HD, Parikh KH, Chag MC, et al. (2007). Beneficial effects of the addition of fenofibrate to statin therapy in patients with acute coronary syndrome after percutaneous coronary interventions. Exp Clin Cardol.
196 Taylor AJ, Sullenberger LE, Lee HJ, et al. (2004). Arterial Biology for the Investigation of the Treatment Effects of Reducing Cholesterol (ARBITER) 2: a double-blind, placebo-controlled study of extended-release niacin on atherosclerosis progression in secondary prevention patients treated with statins [see comment][erratum appears in Circulation. 2004 Dec 7;110(23):3615]. Circulation.
197 Kuvin JT, Dave DM, Sliney KA, et al. (2006). Effects of extended-release niacin on lipoprotein particle size, distribution, and inflammatory markers in patients with coronary artery disease. Am J Cardiol.
198 Simons LA. (1998). Comparison of atorvastatin alone versus simvastatin +/− cholestyramine in the management of severe primary hypercholesterolaemia (the six cities study). Aust N Z J Med.
199 Meyer BJ, Hammervold T, Rustan AC, et al. (2007). Dose-dependent effects of docosahexaenoic acid supplementation on blood lipids in statin-treated hyperlipidaemic subjects. Lipids.
200 Geiss HC, Otto C, Parhofer KG. (2006). Effect of ezetimibe on low-density lipoprotein subtype distribution: results of a placebo-controlled, double-blind trial in patients treated by regular low-density lipoprotein apheresis and statins. Metabolism.
201 Pearson T, Denke M, McBride P, et al. (2005). Effectiveness of the addition of ezetimibe to ongoing statin therapy in modifying lipid profiles and attaining low-density lipoprotein cholesterol goals in older and elderly patients: subanalyses of data from a randomized, double-blind, placebo-controlled trial. Am J Geriatr Pharmacother.
202 Pearson TA, Denke MA, McBride PE, et al. (2006). Effectiveness of ezetimibe added to ongoing statin therapy in modifying lipid profiles and low-density lipoprotein cholesterol goal attainment in patients of different races and ethnicities: a substudy of the Ezetimibe add-on to statin for effectiveness trial. Mayo Clin Proc.
203 Denke M, Pearson T, McBride P, et al. (2006). Ezetimibe added to ongoing statin therapy improves LDL-C goal attainment and lipid profile in patients with diabetes or metabolic syndrome. Diab Vasc Dis Res.
204 Capuzzi DM, Morgan JM, Carey CM, et al. (2004). Rosuvastatin alone or with extended-release niacin: a new therapeutic option for patients with combined hyperlipidemia. Prev Cardiol.
205 Simons L, Tonkon M, Masana L, et al. (2004). Effects of ezetimibe added to on-going statin therapy on the lipid profile of hypercholesterolemic patients with diabetes mellitus or metabolic syndrome. Curr Med Res Opin.
206 Sager PT, Melani L, Lipka L, et al. (2003). Effect of coadministration of ezetimibe and simvastatin on high-sensitivity C-reactive protein. Am J Cardiol.
207 Nordoy A, Svensson B, Hansen JB. (2003). Atorvastatin and omega-3 fatty acids protect against activation of the coagulation system in patients with combined hyperlipemia. J Thromb Haemost.
208 Chan DC, Watts GF, Barrett PH, et al. (2002). Regulatory effects of HMG CoA reductase inhibitor and fish oils on apolipoprotein B-100 kinetics in insulin-resistant obese male subjects with dyslipidemia. Diabetes.
209 Chan DC, Watts GF, Barrett PH, et al. (2002). Effect of atorvastatin and fish oil on plasma high-sensitivity C-reactive protein concentrations in individuals with visceral obesity. Clin Chem.
210 Chan DC, Watts GF, Nguyen MN, et al. (2006). Factorial study of the effect of n-3 fatty acid supplementation and atorvastatin on the kinetics of HDL apolipoproteins A-I and A-II in men with abdominal obesity. Am J Clin Nutr.
211 Nordoy A, Bonaa KH, Sandset PM, et al. (2000). Effect of omega-3 fatty acids and simvastatin on hemostatic risk factors and postprandial hyperlipemia in patients with combined hyperlipemia. Arterioscler Thromb Vasc Biol.
212 Simons LA, Sullivan D, Simons J, et al. (1998). Effects of atorvastatin monotherapy and simvastatin plus cholestyramine on arterial endothelial function in patients with severe primary hypercholesterolaemia. Atherosclerosis.
213 Vanhanen HT, Miettinen TA. (1995). Cholesterol absorption and synthesis during pravastatin, gemfibrozil and their combination. Atherosclerosis.
214 Wiklund O, Bondjers G, Wright I, et al. (1996). Insoluble complex formation between LDL and arterial proteoglycans in relation to serum lipid levels and effects of lipid lowering drugs. Atherosclerosis.
215 Insull JW. (2005). Niacin extended-release with lovastatin for hypercholesterolemia. Cardiol Rev.
216 Bays HE, McGovern ME. (2003). Once-daily niacin extended release/lovastatin combination tablet has more favorable effects on lipoprotein particle size and subclass distribution than atorvastatin and simvastatin. Prev Cardiol.
217 Bays H. (2003). Combination niacin and statin therapy compared with monotherapy. Cardiol Rev.
218 Bays HE, McGovern ME. (2005). Time as a variable with niacin extended-release/lovastatin vs. atorvastatin and simvastatin. Prev Cardiol.
219 Taylor AJ, Zhu D, Sullenberger LE, et al. (2007). Relationship between glycemic status and progression of carotid intima-media thickness during treatment with combined statin and extended-release niacin in ARBITER 2. Vasc Health Risk Manag.
220 Athyros VG, Mikhailidis DP, Didangelos TP, et al. (2006). Effect of multifactorial treatment on non-alcoholic fatty liver disease in metabolic syndrome: A randomised study. Curr Med Res Opin.
221 Pearson T, Ballantyne C, Sisk C, et al. (2007). Comparison of effects of ezetimibe/simvastatin versus simvastatin versus atorvastatin in reducing C-reactive protein and low-density lipoprotein cholesterol levels. Am J Cardiol.
222 Abate N, Catapano AL, Ballantyne CM, et al. (2008). Effect of ezetimibe/simvastatin versus atorvastatin or rosuvastatin on modifying lipid profiles in patients with diabetes, metabolic syndrome, or neither: Results of two subgroup analyses[(a)]. J Clin Lipidology.
223 Ballantyne CM, Lipka LJ, Sager PT, et al. (2004). Long-term safety and tolerability profile of ezetimibe and atorvastatin coadministration therapy in patients with primary hypercholesterolaemia. Int J Clin Pract.
224 Tanaka K, Ishikawa Y, Yokoyama M, et al. (2008). Reduction in the recurrence of stroke by eicosapentaenoic acid for hypercholesterolemic patients: subanalysis of the JELIS trial. Stroke.
225 Guyatt GH, Oxman AD, Vist GE, et al. (2008). GRADE: an emerging consensus on rating quality of evidence and strength of recommendations. BMJ.
226 Josan K, Majumdar SR, McAlister FA. (2008). The efficacy and safety of intensive statin therapy: a meta-analysis of randomized trials. CMAJ.
227 Studer M, Briel M, Leimenstoll B, et al. (2005). Effect of different antilipidemic agents and diets on mortality: a systematic review [review] [20 refs]. Arch Intern Med.
228 Saha SA, Kizhakepunnur LG, Bahekar A, et al. (2007). The role of fibrates in the prevention of cardiovascular disease—a pooled meta-analysis of long-term randomized placebo-controlled clinical trials. Am Heart J.
229 Amarenco P, Lavallee P, Touboul PJ. (2004). Stroke prevention, blood cholesterol, and statins. Lancet Neurol.
230 Goldstein LB, Amarenco P, Szarek M, et al. (2008). Hemorrhagic stroke in the Stroke Prevention by Aggressive Reduction in Cholesterol Levels study. Neurology.
231 Lewington S, Whitlock G, Clarke R, et al. (2007). Blood cholesterol and vascular mortality by age, sex, and blood pressure: a meta-analysis of individual data from 61 prospective studies with 55,000 vascular deaths. Lancet.
232 Rossouw JE, Lewis B, Rifkind BM. (1990). The value of lowering cholesterol after myocardial infarction. N Engl J Med.
233 Pekkanen J, Linn S, Heiss G, et al. (1990). Ten-year mortality from cardiovascular disease in relation to cholesterol level among men with and without preexisting cardiovascular disease. N Engl J Med.
234 Wong ND, Wilson PW, Kannel WB. (1991). Serum cholesterol as a prognostic factor after myocardial infarction: the Framingham Study. Ann Intern Med.
235 Lloyd-Jones DM, Larson MG, Beiser A, et al. (1999). Lifetime risk of developing coronary heart disease. Lancet.
236 Law MR, Wald NJ, Thompson SG. (1994). By how much and how quickly does reduction in serum cholesterol concentration lower risk of ischaemic heart disease?. BMJ.
237 Law MR. (1999). Lowering heart disease risk with cholesterol reduction: evidence from observational studies and clinical trials. European heart journal Supplements.
238 Law MR, Wald NJ, Rudnicka AR. (2003). Quantifying effect of statins on low density lipoprotein cholesterol, ischaemic heart disease, and stroke: systematic review and meta-analysis [see comment] [review] [14 refs]. BMJ.
239 Beil U, Crouse JR, Einarsson K, et al. (1982). Effects of interruption of the enterohepatic circulation of bile acids on the transport of very low density-lipoprotein triglycerides. Metabolism.
240 Davis HR, Veltri EP. (2007). Zetia: inhibition of Niemann-Pick C1 Like 1 (NPC1L1) to reduce intestinal cholesterol absorption and treat hyperlipidemia [review] [46 refs]. J Atheroscler Thromb.
241 Fazio S, Linton MF. (2004). The role of fibrates in managing hyperlipidemia: mechanisms of action and clinical efficacy [review] [81 refs]. Curr Atheroscler Rep.
242 Smilde TJ, van WS, Wollersheim H, et al. (2001). Effect of aggressive versus conventional lipid lowering on atherosclerosis progression in familial hypercholesterolaemia (ASAP): a prospective, randomised, double-blind trial. Lancet.
243 [Abbott Laboratories]. Niaspan tablets: Niaspan extended-release tablets [product monograph #303-157519].
244 Davidson MH, Robinson JG. (2007). Safety of aggressive lipid management [review] [66 refs]. J Am Coll Cardiol.
245 Sokol MC, McGuigan KA, Verbrugge RR, et al. (2005). Impact of medication adherence on hospitalization risk and healthcare cost. Med Care.
246 Balkrishnan R. (2005). The importance of medication adherence in improving chronic-disease related outcomes: what we know and what we need to further know. Med Care.
247 Kripalani S, Yao X, Haynes RB. (2007). Interventions to enhance medication adherence in chronic medical conditions: a systematic review. Arch Intern Med.
248 Gazmararian JA, Kripalani S, Miller MJ, et al. (2006). Factors associated with medication refill adherence in cardiovascular-related diseases: a focus on health literacy. J Gen Intern Med.
249 Balkrishnan R. (1998). Predictors of medication adherence in the elderly. Clin Ther.
250 Kane SV, Brixner D, Rubin DT, et al. (2008). The challenge of compliance and persistence: focus on ulcerative colitis. J Manag Care Pharm.
251 Ioannidis JP, Trikalinos TA. (2007). The appropriateness of asymmetry tests for publication bias in meta-analyses: a large survey. CMAJ.
252 (2008). Standards of medical care in diabetes—2008. Diabetes Care.
253 Brunzell JD, Davidson M, Furberg CD, et al. (2008). Lipoprotein management in patients with cardiometabolic risk: consensus conference report from the American Diabetes Association and the American College of Cardiology Foundation. J Am Coll Cardiol.
254 Goff DC, Bertoni AG, Kramer H, et al. (2006). Dyslipidemia prevalence, treatment, and control in the Multi-Ethnic Study of Atherosclerosis (MESA): gender, ethnicity, and coronary artery calcium. Circulation.
255 Passel JS, Cohn D. U.S. Population Projections: 2005–2050.
256 Deedwania P, Stone PH, Bairey Merz CN, et al. (2007). Effects of intensive versus moderate lipid-lowering therapy on myocardial ischemia in older patients with coronary heart disease: results of the Study Assessing Goals in the Elderly (SAGE). Circulation.
257 Robinson JG, Davidson MH, Shah A, et al. (2007). Efficacy and safety of ezetimibe and ezetimibe plus statin therapy in patients aged under 65, 65–74 and 75 years and older. Aging Health.
258 Koenig W, Lowel H, Baumert J, et al. (2004). C-reactive protein modulates risk prediction based on the Framingham Score: implications for future risk assessment: results from a large cohort study in southern Germany. Circulation.
259 Ridker PM, Danielson E, Fonseca FA, et al. (2008). Rosuvastatin to prevent vascular events in men and women with elevated C-reactive protein. N Engl J Med.