# Appendix H GRADE Tables, Assessing the Evidence

The following is compiled from GRADEProfiler software (version 3.2) and reproduced with permission, for convenience of the reader. A handbook with all recommendations can be found in: Schünemann H, Brozek J, Oxman A, editors. GRADE handbook for grading quality of evidence and strength of recommendation. Version 3.2 [updated March 2008]. The GRADE Working Group, 2008. Available from http://www.cc-ims.net/gradepro.

## GRADE Working Group: Grades of Evidence

High quality: Further research is very unlikely to change our confidence in the estimate of effect.

Moderate quality: Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.

Low quality: Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Very low quality: We are very uncertain about the estimate.

## GRADE Working Group: Rating the Quality of Evidence

### Limitations to Evidence

Parameters | Rated as NO limitation | Rated as SERIOUS limitation | Rated as VERY SERIOUS limitation
Limitation in design | Negligible limitation | This may downgrade the quality of evidence by 1 level | This may downgrade the quality of evidence by 2 levels
Inconsistency | Negligible limitation | This may downgrade the quality of evidence by 1 level | This may downgrade the quality of evidence by 2 levels
Indirectness | Negligible limitation | This may downgrade the quality of evidence by 1 level | This may downgrade the quality of evidence by 2 levels
Imprecision | Negligible limitation | This may downgrade the quality of evidence by 1 level | This may downgrade the quality of evidence by 2 levels
Publication bias | Negligible limitation | This may downgrade the quality of evidence by 1 level | This may downgrade the quality of evidence by 2 levels

### Explanation of Parameters

Parameter 1: Limitations to design of randomized controlled trials

Limitation | Explanation
Lack of allocation concealment Lack of blinding Incomplete accounting of patients and outcome events Selective outcome reporting Other limitations | Those enrolling patients are aware of the group to which the next enrolled patient will be allocated (major problem in “pseudo” or “quasi” randomized trials with allocation by day of week, birth date, chart number etc.) Patient, caregivers, those recording outcomes, those adjudicating outcomes, or data analysts are aware of the arm to which patients are allocated Loss to follow-up and failure to adhere to the intention to treat principle when indicated Reporting of some outcomes and not others on the basis of the results For example:; - stopping early for benefit observed in randomized trials, in particular in the absence of adequate stopping rules; - use of unvalidated patient-reported outcomes; - carry-over effects in cross-over trials; - recruitment bias in cluster-randomized trials

Parameter 2: Inconsistency of results or unexplained heterogeneity

When heterogeneity exists, but investigators fail to identify a plausible explanation, the quality of evidence should be downgraded by one or two levels, depending on the magnitude of the inconsistency in the results.

Inconsistency may arise from differences in:

- populations (e.g. drugs may have larger relative effects in sicker populations)
- interventions (e.g. larger effects with higher drug doses)
- outcomes (e.g. diminishing treatment effect with time).

Parameter 3: Indirectness of evidence (note: Indirect comparisons were not made in the present work)

1. Indirect comparison – occurs when a comparisons of intervention A versus B is not available, but A was compared with C and B was compared with C. Such studies allow indirect comparisons of the magnitude of effect of A versus B. Such evidence is of lower quality than head-to-head comparisons of A and B would provide.
2. Indirect population, intervention, comparator, or outcome – the question being addressed by the guideline panel or by the authors of a systematic review is different from the available evidence regarding the population, intervention, comparator, or an outcome.

Parameter 4: Imprecision of results [dichotomous outcomes]

GRADE Working Group suggest downgrading the quality of evidence for any of the following three reasons:

1. total (cumulative) sample size is lower than the calculated “optimal information size” (OIS). OIS represents the number of patients generated by a conventional sample size calculation specifying a particular alpha and beta error, relative risk reduction, and baseline event rate.
2. total number of events is less than 300.
3. 95% confidence interval (or alternative estimate of precision) around the pooled or best estimate of effect includes both negligible effect and appreciable benefit or appreciable harm. GRADE suggests that threshold for "appreciable benefit" or "appreciable harm" that should be considered for downgrading is a relative risk reduction (RRR) or relative risk increase (RRI) greater than 25%.

Parameter 5: Publication bias

Publication bias arises when investigators fail to report studies they have undertaken (typically those that show no effect). Methods to detect the possibility of publication bias in systematic reviews exist, although authors of the reviews must often guess about the likelihood of publication bias. A prototypical situation that should elicit suspicion of publication bias occurs when published evidence is limited to a small number of trials, all of which are showing benefits of the studied intervention.

The following abbreviations apply to all GRADE tables in Appendix H: ATP III LDL-c goals = Adult Treatment Panel low density lipoprotein cholesterol goals (of the National Cholesterol Education Program), OR = odds ratio, BAS = Bile acid sequestrants, CI = confidence interval, LDL-c = low density lipoprotein cholesterol, HC = hypercholesterolemia, CAD = coronary artery diseases, CHD = coronary heart diseases, T2DM = type 2 diabetes mellitus

### Operationalization of Parameters

Parameters | Rated as NO limitation | Rated as SERIOUS limitation | Rated as VERY SERIOUS limitation
Limitation in design | - Adequate allocation concealment; - Adequate blinding procedure; - Intention-to-treat analysis | Not all parameters were fulfilled, although some studies reported adequate allocation concealment or blinding or ITT | All parameters were unclear or inadequate
Inconsistency | - No substantial heterogeneity (I- squared 50% or less); - Populations in need of intensive treatment and subgroups; - Evidence-based on a single study | - Not all parameters were fulfilled. For example, although analysis could be pooled for a common drug effect, populations were clinically diverse; - Analysis of various doses and statins were considered inconsistent | Diverse population and Substantial statistical heterogeneity
Indirectness | - All studies were direct comparative trials; - Populations in need of intensive treatment and subgroups | - Analysis of various statin doses; - Analysis in populations other than in need of intensive treatment or subgroups | Not used in the current review
Imprecision | 95% confidence interval around the pooled data (or single estimate) was precise | - Wide 95% confidence interval (or alternative estimate of precision) around the pooled or best estimate of effect and including both negligible effect and appreciable benefit or appreciable harm; - No events reported in a particular outcome; - If data not pooled and total number of events on evaluable participants were less than 300 | Very wide 95% confidence interval (or alternative estimate of precision) around the pooled or best estimate of effect and including both negligible effect and appreciable benefit or appreciable harm
Publication bias | Evidence based in more than 10 trials with nonsignificant Egger’s test | Evidence is limited to 10 or fewer trials limiting interpretation of publication bias | Evidence based in more than 10 trials with significant Egger’s test for asymmetry

Parameters not used
Limitation in design | Selective reporting outcome and/or other limitations – as it was not collected in our review
Inconsistency | Outcomes were given the same strength, as we decided in 3 clinical outcomes and 1 surrogate outcome judge to be as relevant as the clinical outcomes
Indirectness | Outcomes were given the same strength, as we decided in 3 clinical outcomes and 1 surrogate outcome judge to be as relevant as the clinical outcomes
Imprecision | Total sample size being lower that the calculated OIS

## GRADE: Ezetimibe-Statin Combination Therapy Compared With Statin Monotherapy

Table H-1

GRADE: Ezetimibe-lower dose simvastatin combination therapy versus higher dose simvastatin monotherapy in participants requiring intensive lipid-lowering therapy

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Lower dose simvastatin- ezetimibe combination therapy | higher dose simvastatin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 12–24 weeks)
2 | randomised trial | very serious^1^ | no serious inconsistency^2^ | no serious indirectness | very serious^1^ | reporting bias^1^ | 0/214 (0%) | 0/225 (0%) | not pooled | not pooled | VERY LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | none | 0/0 (0%) | 0/0 (0%) | - | - | | CRITICAL
Participants reaching ATP III LDL-c goals (follow-up 12–24 weeks)
3 | randomised trial^3^ | very serious^4^ | serious^5^ | no serious indirectness | very serious^5^ | reporting bias^4^ | 198/256 (77.3%) | 188/396 (47.5%) | not pooled | not pooled | VERY LOW | IMPORTANT

1 Two trials reporting no deaths during a 12–24 weeks followup.121,151 One of the trials reported an appropriate method of randomization,151 no trial described method of allocation concealment, double-blind procedure and intention-to-treat analysis.

2 Participants with T2DM on stable medication, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dl

3 Fixed and/or conditional titration

4 Three trials included.47,121,151 One 12-week trial described appropriate method of randomization, and performed an intention-to-treat analysis for ATP III target outcome.151 None of the trials described double-blind procedure. Participants required intensive lipid-lowering therapy because of T2DM121,151 and/or CHD risk equivalent.47,151

5 Data could not be pooled because of significant heterogeneity (I-squared = 60%)

Table H-2

GRADE: Ezetimibe-statin combination therapy versus statin monotherapy in participants requiring intensive lipid-lowering therapy

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Ezetimibe- statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 6–24 )
14^1^ | randomised trial | serious1,2 | serious^2^ | serious^2^ | serious^3^ | none | 6/3122 (0.2%) | 9/3153 (0.3%) | OR 0.61 (0.22 to 1.71) | 1 fewer per 1000 (from 2 fewer to 2 more) | VERY LOW | CRITICAL
Vascular death (follow-up mean 96 weeks)
1 | randomised trial | serious^4^ | no serious inconsistency | serious^4^ | serious^4^ | reporting bias^4^ | 2/357 (0.6%) | 1/363 (0.3%) | OR 1.98 (0.21 to 19.14)^5^ | 3 more per 1000 (from 2 fewer to 51 more) | VERY LOW | CRITICAL
Participants reaching ATP III LDL-c goals (follow-up 6–24 weeks)
18 | randomised trial | serious^6^ | very serious6,7 | serious^6^ | serious^7^ | none | 3509/4265 (82.3%) | 1833/3466 (52.9%) | not pooled | not pooled | VERY LOW | IMPORTANT

1 Seven trials reported no deaths.114,116,121,140,151,159,193

2 One long-term 121 and 13 short-term trials comparing different statins and different doses were included; funnel plot did not show significant asymetry.114–116,118,140,142–144,149,151,159,193,194 Six trials reported adequate allocation concealment,118,144,149,159,193,194 four reported an appropriate double-blind procedure,114–116,159 and one reported intention-to-treat analyses.140

3 Wide confidence intervals in each single trial and pooled data

4 Single 96 weeks study comparing same dose statin in both arms. 42 Study reported adequate allocation concealment and three vascular deaths.42 Double-blind, and intention-to-treat analysis procedures were not reported.42

5 Peto OR

6 Eighteen short-term trials comparing different statins and different doses were included; funnel plot did not show significant asymetry.47,112,114–118,121,140,142,144,148,149,151,167,168,193,194 Seven trials reported an adequate allocation concealment,117,118,144,148,149,193,194 four appropriate double-blind procedure,114–116,148 and four reported intention-to-treat analyses140,148,151,168

7 Results not pooled because of significant heterogeneity (I-squared 90%). Participants required intensive lipid-lowering therapy because of primary HC (8 studies), HC with CAD (3 studies), CHD risk equivalent (3 studies), and DM (4 studies)

Table H-3

GRADE: Ezetimibe-statin combination therapy versus statin monotherapy in participants with baseline LDL-c > 190 mg/dL

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Ezetimibe- statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality - not measured
0 | - | - | - | - | - | none | - | - | - | - | | CRITICAL
Vascular death (follow-up mean 96 weeks)
1 | randomised trial | serious^1^ | no serious inconsistency | serious^1^ | serious^1^ | reporting bias^1^ | 2/357 (0.6%) | 1/363 (0.3%) | OR 1.98 (0.21 to 19.14)^2^ | 3 more per 1000 (from 2 fewer to 51 more) | VERY LOW | CRITICAL
Participants reaching ATP III LDL-c goals - not measured
0 | - | - | - | - | - | None | - | - | - | - | | IMPORTANT

1 Single 96 weeks study comparing same dose statin in both arms. 42 Study reported adequate allocation concealment and three vascular deaths.42 Double-blind, and intention-to-treat analysis procedures were not reported.42

2 Peto OR

Table H-4

GRADE: Ezetimibe-statin combination therapy versus statin monotherapy in participants with diabetes mellitus

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Ezetimibe- statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 6–24 weeks)
6 | randomised trial | serious^1^ | serious^1^ | serious^1^ | serious^2^ | reporting bias^1^ | 2/1509 (0.1%) | 4/1507 (0.3%) | OR 0.40 (0.08 to 2.09) | 2 fewer per 1000 (from 3 fewer to 3 more) | VERY LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | None | - | - | - | - | | CRITICAL
Participants reaching ATP III LDL-c goals (follow-up 6–24 weeks)
9 | randomised trial | serious^3^ | very serious3,4 | serious^3^ | serious^4^ | reporting bias^3^ | 2055/2474 (83.1%) | 1074/1866 (57.6%) | not pooled | not pooled | VERY LOW | IMPORTANT

1 A 24-week trial with unclear allocation concealment, double-blind procedure and no intention-to-treat analysis reported no deaths.121 Data from five 6–12 week trials reporting 6 deaths were pooled.118,144,149,193,194 All 6–12 week trials reported adequate allocation concealment, none reported double-blind procedure or intention-to-treat analysis. Included trials compared different statins and different doses.

2 Wide confidence intervals in each single trial and pooled data

3 Nine 6–24 week trials comparing different statins and different doses were included.115,117,118,121,144,149,167,193,194 Six trials reported adequate allocation concealment,117,118,144,193,194,259 one reported appropriate double-blind procedure,115 and none performed intention-to-treat analysis.

4 Short-term trials with significant heterogeneity (I-squared = 91%)

Table H-5

GRADE: Ezetimibe-statin combination therapy versus statin monotherapy in participants with established vascular disease

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Ezetimibe- statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 6–12 weeks)
6 | randomised trial | serious^1^ | serious^1^ | serious^1^ | serious^2^ | reporting bias^1^ | 4/970 (0.4%) | 6/993 (0.6%) | OR 0.66 (0.19 to 2.31) | 2 fewer per 1000 (from 5 fewer to 8 more) | VERY LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | None | - | - | - | - | | CRITICAL
Participants reaching ATP III LDL-c goals (follow-up 6–12 weeks)
6 | randomised trial | serious^3^ | very serious3,4 | serious^3^ | serious^4^ | reporting bias^4^ | 785/956 (82.1%) | 346/966 (35.8%) | not pooled | not pooled | VERY LOW | IMPORTANT

1 Six short-term trials comparing different statins and different doses were included,114–116,140,143,149 three trials reported no deaths.114,116,140 One trial reported adequate allocation concealment,149 three reported appropriate double-blind procedure,114–116 and one performed intention-to-treat analysis.140

2 Wide confidence intervals in each single trial and pooled data.

3 Six short-term trials comparing different statins and different doses were included,114–116,140,149,168 three trials reported no deaths.114,116,140 One trial reported adequate allocation concealment,149 three reported appropriate double-blind procedure,114–116 and two performed intention-to-treat analysis.140,168

4 All studies favored combination therapy, however, due to significant heterogeneity (I-squared 72%) data was not pooled.

Table H-6

GRADE: Ezetimibe-statin combination therapy versus statin monotherapy in participants of African descent

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Ezetimibe- statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up mean 12 weeks)
1 | randomised trial^1^ | serious1,2 | no serious inconsistency | serious^2^ | very serious^1^ | reporting bias^1^ | 0/124 (0%) | 0/123 (0%) | - | - | VERY LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | None | - | - | - | - | | CRITICAL
Participants reaching ATP III LDL-c goals (follow-up mean 6 weeks)
1 | randomised trial | very serious^3^ | no serious inconsistency | serious^3^ | no serious imprecision | reporting bias 3 | 85/135 (63%) | 24/73 (32.9%) | OR 3.47 (1.9 to 6.33) | 437 more per 1000 (from 201 more to 683 more) | VERY LOW | IMPORTANT

1 A single RCT with no deaths in combination or monotherapy was identified111

2 A 12 week trial comparing the same dose of simvastatin in both arms, with an adequate allocation concealment and double-blind procedure, no intention-to-treat analysis111

3 Data from a sub-group population of a single 6 weeks trial comparing mixed statins in combination and monotherapy.117 Main RCT with adequate allocation concealment; double blind procedure not described, no intention-to-treat analysis performed.117

Table H-7

GRADE: Ezetimibe-statin combination versus statins monotherapy in participants of Hispanic descent

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Ezetimibe- statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality - not measured
0 | - | - | - | - | - | None | - | - | - | - | | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | None | - | - | - | - | | CRITICAL
Participants reaching ATP III LDL-c goals (follow-up mean 6 weeks)
1 | randomised trial | very serious^1^ | no serious inconsistency | serious^1^ | serious | reporting bias^1^ | 46/71 (64.8%) | 8/42 (19%) | OR 7.82 (3.14 to 19.45) | 576 more per 1000 (from 271 more to 854 more) | VERY LOW | IMPORTANT

1 Data from a sub-group population of a single 6 weeks trial comparing mixed statins in combination and monotherapy.117 Main RCT with adequate allocation concealment; double blind procedure not described, no intention-to-treat analysis performed.117

Table H-8

GRADE: Ezetimibe-statin combination versus statins monotherapy in female participants

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Ezetimibe- statin combination | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause-mortality (follow-up 4–12 weeks)
2 | randomised trial | serious^1^ | serious^1^ | serious^1^ | very serious1,2 | reporting bias^1^ | 1/72 (1.4%) | 1/56 (1.8%) | OR 0.95 (0.06 to 15.75) | 1 fewer per 1000 (from 17 fewer to 208 more) | VERY LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | None | - | - | - | - | | CRITICAL
Participants reaching ATP III LDL-c goals (follow-up 6–12 weeks)
2 | randomised trial | very serious^3^ | very serious3,4 | serious^3^ | very serious^4^ | reporting bias^3^ | 74/96 (77.1%) | 30/93 (32.3%) | not pooled | not pooled | VERY LOW | IMPORTANT

1 Data analyzed is a sub-group of the whole trial population. A 4-week trial described adequate allocation concealment, double blind procedure and performed intention-to-treat analysis.169 A 12-week trial described an adequate allocation concealment, but did not report double-blind procedure or performed intention-to-treat analysis.149 Trials compared different statins and different statin doses.

2 Wide confidence interval.

3 A sub-group of two trials provided data for this outcome.114,149 One trial described an appropriate allocation concealment,149 one described an appropriate double-blind procedure,114 and none performed an intention-to-treat analysis. Trials compared different statins and different statin doses.

4 Data could not be pooled because of significant heterogeneity (I-squared = 87%)

Table H-9

GRADE: Ezetimibe-lower dose simvastatin combination therapy versus higher dose simvastatin monotherapy in all participants

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Lower dose simvastatin- ezetimibe combination therapy 11 | higher dose simvastatin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 4–24 weeks)
3 | randomised trial | serious1,2 | serious^2^ | serious^2^ | very serious^1^ | reporting bias^1^ | 0/248 (0%) | 0/291 (0%) | not pooled | not pooled | VERY LOW | CRITICAL
Vascular death (follow-up mean 12 weeks)
1 | randomised trial | serious^3^ | no serious inconsistency | no serious indirectness | very serious^4^ | reporting bias^3^ | 1/119 (0.8%) | 0/123 (0%) | OR 8.05 (0.16 to 407.27)^5^ | 0 more per 1000 (from 0 fewer to 0 more) | VERY LOW | CRITICAL
Serious adverse events (follow-up 4–24 weeks)
3 | randomised trial | serious^6^ | serious^7^ | no serious indirectness | serious^4^ | reporting bias^6^ | 31/530 (5.8%) | 13/397 (3.3%) | OR 1.64 (0.85 to 3.19) | 20 more per 1000 (from 5 fewer to 66 more) | VERY LOW | CRITICAL
Participants reaching ATP III LDL-c goals (follow-up 12–24 weeks)
3 | randomised trial | very serious^8^ | serious9,10 | no serious indirectness | very serious^10^ | reporting bias^8^ | 198/256 (77.3%) | 188/396 (47.5%) | not pooled | not pooled | VERY LOW | IMPORTANT

1 Three 4–24 week trials were included and reported no deaths.121,151,169 Two trials described an appropriate method of randomization.151,169 One 4-week trial described adequate allocation concealment, double-blind procedure, and reported an intention-to-treat analysis.169

2 Two trials reported that all participants diagnosed with T2DM on stable medication.121,151 In the third trial, participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day.169

3 One 12 week trial reported one vascular death.130 This trial had an adequate allocation concealment and double-blind procedure, and did not perform an intention-to-treat analysis. However, only 2 of the 8 arms in this trial contributed data for this outcome130

4 Wide confidence interval.

5 Peto OR

6 Three 4–24 week trials were included.47,121,169 One 4 week trial described adequate allocation concealment, double-blind procedure, and reported an intention-to-treat analysis.169 All participants required intensive lipid-lowering therapy because of T2DM121 or CHD risk equivalent.47,151

7 One trial reported that all participants diagnosed with T2DM on stable medication.121 In two trials, participants of mixed 10 year CHD risk.47,169

8 Three trials included.47,121,151 One 12-week trial described adequate allocation concealment, and performed an intention-to-treat analysis.151 None of the trials described appropriate double-blind procedure. All participants required intensive lipid-lowering therapy because of T2DM121,151 or CHD risk equivalent.47,151

9 Two trials reported that all participants diagnosed with T2DM on stable medication.121,151 In one trial, participants of mixed 10 year CHD risk.47

10 Data could not be pooled because of significant heterogeneity (I-squared = 60%)

11 Fixed and/or conditional titration

Table H-10

GRADE - Ezetimibe-statin combination therapy versus statin monotherapy in all participants followed for more than 24 weeks

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Ezetimibe- statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 24–52 weeks)
4 | randomised trial | very serious^1^ | Serious1,2 | Serious^1^ | very serious^2^ | reporting bias^1^ | 3/942 (0.3%) | 0/486 (0%) | OR 7.51 (0.38 to 147.37) | 0 more per 1000 (from 0 fewer to 0 more) | VERY LOW | CRITICAL
Vascular death (follow-up 96 weeks)
1 | randomised trial | no serious limitations^3^ | no serious inconsistency | no serious indirectness | very serious^3^ | reporting bias^3^ | 2/357 (0.6%) | 1/363 (0.3%) | OR 1.98 (0.21 to 19.14) | 3 more per 1000 (from 2 fewer to 51 more) | VERY LOW | CRITICAL
Serious adverse events (follow-up 24–52 weeks)
6 | randomised trial | serious^4^ | serious4,5,6 | serious^4^ | serious^6^ | reporting bias^4^ | 137/1329 (10.3%) | 54/564 (9.6%) | not pooled | not pooled | VERY LOW | CRITICAL
Participants reaching ATP III LDL-c goals - not measured
0 | - | - | - | - | - | None | - | - | - | - | | IMPORTANT

1 Four 24–52 week trials comparing different statins and different statin doses were included,48,121,126,166 3 reported no deaths.48,121,126 Two trials reported an adequate allocation concealment,48,166 one described an appropriate double-blind procedure,48 and one trial performed an intention-to-treat analysis.166

2 Results based on 3 deaths, and only one trial with analyzable data166 In this trial, participants were diagnosed with renal disease and without definitive indication for cholesterol lowering

3 A 96 week trial reporting 3 vascular deaths comparing same dose statin in both arms was included.42 This trial reported an adequate allocation concealment and appropriate double-blind procedure, no intention-to-treat analysis was performed.42 All participants with familial hypercholesterolemia and LDL-c > 210 mg/dl.

4 Six trials comparing different statins and different statin doses were included.48,121,126,130,166,167. Three trials described adequate allocation concealment,48,130,166 and one trial described intention-to-treat analysis166. An appropriate procedure for double-blinding was not described.

5 Participants of mixed risk in four trials,48,126,130,166 primary hypercholestromia,167 or T2DM on stable medication.121

6 Results not pooled because of significant heterogeneity (I-squared = 56%)

Table H-11

GRADE - Ezetimibe-statin combination therapy versus statin monotherapy in all participants

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Ezetimibe- statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 2–52 weeks)
24 | randomised trial | serious^1^ | Serious1,2 | serious^1^ | serious^2^ | none | 9/7867 (0.1%) | 9/6540 (0.1%) | OR 0.95 (0.37 to 2.41)^3^ | 0 fewer per 1000 (from 1 fewer to 1 more) | VERY LOW | CRITICAL
Vascular death (follow-up 12–96 weeks)
2 | randomised trial | very serious^4^ | serious^5^ | serious^5^ | very serious^4^ | reporting bias^4^ | 3/596 (0.5%) | 1/600 (0.2%) | OR 2.70 (0.38 to 19.2)^3^ | 3 more per 1000 (from 1 fewer to 35 more) | VERY LOW | CRITICAL
Serious adverse events (follow-up 4–52)
27 | randomised trial | serious^6^ | serious^6^ | serious^6^ | no serious imprecision | none | 297/7094(4.2%) | 192/6369 (3%) | OR 1.08 (0.88 to 1.33) | 3 more per 1000 (from 1 fewer to 35 more) | VERY LOW | CRITICAL
Participants reaching ATP III LDL-c goals (follow-up 6–24 weeks)
23 | randomised trial | serious^7^ | Very serious7,8,9 | serious^7^ | serious^9^ | none | 6992/8646 (80.9%) | 4337/7298 (59.4%) | not pooled | not pooled | VERY LOW | IMPORTANT

1 Twenty four 2–52 week trials comparing different statins and different statin doses were included; funnel plot did not show significant asymetry 48,110,111,114–118,121,126,127,129,140,142–144,149,151,158,159,166,169,193,194 16 trials reported no deaths.48,110,111,114,116,117,121,126,127,129,140,151,158,159,169,193 Eight trials described an adequate allocation concealment,118,144,149,158,159,166,169,194 4 trials described an appropriate double-blind procedure,115,158,159,169 and 5 trials performed an intention-to-treat analysis.110,151,166,169,187

2 Results based on mixed population with scarce number of deaths (18 in total), and all but one trial166 had a short-term follow up.

3 Peto OR

4 Two 12–96 week trials reported 4 vascular deaths.42,130 Both studies reported an adequate allocation concealment, but did not describe an appropriate double-blind procedure, nor performed an intention-to-treat analysis.

5 One short-term trial was performed in a mixed risk population,130 and one long-term trial in participants with familial hypercholesterolemia and LDL-c > 210 mg/dl.42 All trials have used simvastatin with different doses.

6 Twenty seven 2–52 week trials comparing different statins and different statin doses were included; funnel plot did not show significant asymetry47,48,110–112,114–116,118,121,126,130,140,142–144,149,151,154,156,158,159,166–169,193 Three trials did not report any SAEs.110,158,168 Twelve trials described an adequate allocation concealment,48,111,118,130,144,149,154,158,159,166,169,193 9 trials described appropriate double-blind procedure,48,111,114–116,154,158,159,169 and 6 trials described intention-to-treat analysis110,140,156,166,168,169

7 23 short-term trials comparing different statins and different statin doses were included; funnel plot did not show significant asymetry.47,112,114–118,121,126,127,129,130,140,142,144,148,149,151,156,167,168,193,194 9 trials described adequate allocation concealment,117,118,127,130,144,148,149,193,194 4 trials described appropriate double-blind procedure,114–116,148 and 7 trials described intention-to-treat analysis127,129,140,148,151,156,168

8 Participants with mixed risk: vascular disease,112 CAD,114–116,140, not ATP III target,117,118,167, CHD risk equivalent,47,142 DM.121,144,151,156,194, and primary hypecholeterolemia.126,127,129,130,148,149,168,193

9 Results based only on short-term trials, with significant heterogeneity (I-squared = 93%)

## GRADE: Fibrate-Statin Combination Therapy Compared With Statin Monotherapy

Table H-12

GRADE: Fenofibrate (67 mg/day)-Rosuvastatin (5–10 mg/day) combination therapy versus rosuvastatin (40 mg/day) in participants requiring intensive lipid-lowering therapy

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Fenofibrate (67 mg/day)- rosuvastatin (5–10 mg/day) combination therapy | rosuvastatin (40 mg/day) monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 18 weeks)
1 | randomised trial | very serious^1^ | no serious inconsistency | no serious indirectness | very serious1,2 | reporting bias^2^ | 1/113 (0.9%) | 1/53 (1.9%) | OR 0.46 (0.03 to 7.57) | 11 fewer per 1000 (from 18 fewer to 109 more) | VERY LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | none | - | - | - | - | | CRITICAL
Serious Adverse events - not reported
0 | - | - | - | - | - | none | - | - | - | - | | CRITICAL
Participants reaching ATPIII LDL-c goals (follow-up 18 weeks)
1 | randomised trial | very serious^1^ | no serious inconsistency | no serious indirectness | very serious1,2 | reporting bias^2^ | 83/113 (73.5%) | 43/50 (86%) | OR 0.49 (0.2 to 1.22) | 358 fewer per 1000 (from 630 fewer to 121 more) | VERY LOW | IMPORTANT

1 Single study with unclear allocation concealment, no intention-to-treat analysis reported, short-term follow-up, and very sparse number of events.125

2 Only one of the 11 included trials compared lower dose statin combination with higher dose monotherapy. All participants were diagnosed with T2DM.125

Table H-13

Fibrate-statin combination therapy versus statin monotherapy in participants requiring intensive lipid-lowering therapy

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | all statins plus fibrates | statins monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 18 weeks)
1 | randomised trial | very serious^1^ | no serious inconsistency | no serious indirectness | very serious^1^ | reporting bias^1^ | 1/113 (0.9%) | 1/53 (1.9%) | OR 0.46 (0.03 to 7.57) | 10 fewer per 1000 (from 18 fewer to 109 more) | VERY LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | none | - | - | - | - | | CRITICAL
Serious Adverse Events (follow-up 52 weeks)
1 | randomised trial | very serious^2^ | no serious inconsistency | serious^2^ | very serious^2^ | reporting bias^2^ | 0/25 (0%) | 0/23 (0%) | - | - | VERY LOW | CRITICAL
Participants reaching ATPIII LDL-c goals (follow-up 18–24 weeks)
2 | randomised trial | very serious^3^ | serious^5^ | serious^3^ | very serious^5^ | reporting bias^6^ | 124/153 (81%) | 75/90 (83.3%) | not pooled | not pooled | VERY LOW | IMPORTANT

1 Single study with unclear allocation concealment, no intention-to-treat analysis reported, short-term follow-up, and very sparse number of events.125 All participants on the study had DM.

2 Single study comparing same dose of fluvastatin in both arms, with unclear allocation concealment, no intention-to-treat analysis reported. No SAEs were reported. 123.

3 Two trials comparing different statins and different doses were included,125,161 none reported adequate allocation concealment or an appropriate double-blind procedure, one reported intention-to-treat analyses.161

4 All participants in both trials had diabetes mellitus.125,161

5 Results based on two short-term trials, with significant heterogeneity (I-squared = 84%)

6 Results provided in only two out of 11 included trials.

Table H-14

GRADE: Fibrate-statin combination therapy versus statin monotherapy in participants with diabetes mellitus

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | statins plus fibrates | statins monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 18 weeks)
1 | randomised trial | very serious^1^ | no serious inconsistency | no serious indirectness | very serious1,2 | reporting bias^1^ | 1/113 (0.9%) | 1/53 (1.9%) | OR 0.46 (0.03 to 7.57) | 10 fewer per 1000 (from 18 fewer to 109 more) | VERY LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | none | - | - | - | - | | CRITICAL
Participants reaching ATPIII LDL-c goals (follow-up 18–24 weeks)
2 | randomised trial | very serious^3^ | Serious^4^ | serious^3^ | very serious^4^ | reporting bias^5^ | 124/153 (81%) | 75/90 (83.3%) | not pooled | not pooled | VERY LOW | IMPORTANT

1 Single study with unclear allocation concealment, no intention-to-treat analysis reported, short-term follow-up, and very sparse number of events.125

2 Wide confidence interval.

3 Two trials comparing different statins and different doses were included,125,161 none reported adequate allocation concealment or an appropriate double-blind procedure, one reported intention-to-treat analyses.161

4 Results based on two short-term trials, with significant heterogeneity (I-squared = 84%)

5 Results provided in only two out of 11 included trials

Table H-15

GRADE - Fibrate-statin combination therapy versus statin monotherapy in all participants followed for more than 24 weeks

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Fibrate- statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 48–92 weeks)
1 | randomised trial | very serious^1^ | no serious inconsistency | serious^1^ | very serious^1^ | reporting bias^1^ | 0/14 (0%) | 0/13 (0%) | - | - | VERY LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | none | - | - | - | - | | CRITICAL
Serious Adverse Events (follow-up 52 weeks)
1 | randomised trial | very serious^2^ | no serious inconsistency | serious^2^ | very serious^2^ | reporting bias^2^ | 0/25 (0%) | 0/23 (0%) | - | - | VERY LOW | CRITICAL
Participants reaching ATPIII LDL-c goals (follow-up 24 weeks)
1 | randomised trial | very serious^3^ | no serious inconsistency | serious^3^ | no serious imprecision | reporting bias^3^ | 39/40 (97.5%) | 32/40 (80%) | OR 9.75 (1.16 to 82.11) | 1000 more per 1000 (from 84 more to 1000 more) | VERY LOW | IMPORTANT

1 Single 48–92 week trial same dose of pravastatin in both arms, reported no deaths.188 The study described an unclear allocation concealment, unclear double-blind procedure and no intention-to-treat analysis was reported.188

2 Single 52 week trial comparing same dose of fluvastatin in both arms, reported no SAEs.123 The study described an unclear allocation concealment, unclear double-blind procedure and performed an intention-to-treat analysis.123

3 Single 24 week trial comparing same dose of atorvastatin in both arms was included.161 The study described an unclear allocation concealment, unclear double-blind procedure and performed an intention-to-treat analysis.161

Table H-16

GRADE - Fibrate-statin combination therapy versus statin monotherapy in all participants

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | any statins plus fibrates | statins monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 12–92 weeks)
3 | randomised trial | very serious^1^ | Serious1,2 | Serious1,2 | very serious^3^ | reporting bias^4^ | 1/202 (0.5%) | 2/137 (1.5%) | OR 0.28 (0.03 to 2.97)^5^ | 11 fewer per 1000 (from 15 fewer to 28 more) | VERY LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | none | - | - | - | - | | CRITICAL
Serious Adverse Events (follow-up 12–52 weeks)
2 | randomised trial | serious^6^ | serious6,7 | serious^6^ | serious^7^ | reporting bias^7^ | 12/428 (2.8%) | 5/224 (2.2%) | OR 1.2 (0.42 to3.46) | 4 more per 1000 (from 13 fewer to 50 more) | VERY LOW | CRITICAL
Participants reaching ATPIII LDL-c goals (follow-up 18–24 weeks)
2 | randomised trial | very serious^8^ | very serious^8,9,10^. | serious^8^ | very serious^10^ | reporting bias^11^ | 124/153 (81%) | 75/90 (83.3%) | not pooled | not pooled | VERY LOW | IMPORTANT

1 Three 12–92 week trials comparing different statins and different statin doses were included,125,134,188 one trial reported no deaths.188 All trials described an unclear allocation concealment and did not perform intention-to-treat analysis, one trial described an appropriate double-blind procedure.134

2 Participants in two trials diagnosed with hypercholesterolemia and DM.125,188 No specific risk reported in a third trial.134

3 Wide confidence intervals (individual trials and pooled data).

4 Only 3 out of 11 included trials provided data on all cause mortality

5 Peto OR

6 Two trials comparing different statins and different statin doses were included,120,123 but one reported no serious adverse events.123 One trial reported an adequate allocation concealment,120 and one trial reported and appropriate double-blind procedure and performed an intention-to-treat analysis.123

7 Data analyzed for a single study on which participants had hypercholestoremia.120

8 Two trials comparing different statins and different statin doses were included,125,161 none reported adequate allocation concealment or an appropriate double-blind procedure, one reported intention-to-treat analyses.161

9 All participants in both trials had diabetes mellitus.125,161

10 Results based on two short-term trials, with significant heterogeneity (I-squared = 84%)

11 Results provided in only two out of 11 included trials

## GRADE: Niacin-Statin Combination Therapy Compared With Statin Monotherapy

Table H-17

GRADE: Niacin-statin combination therapy versus statin monotherapy in participants requiring intensive lipid-lowering therapy

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Niacin-statin combination therapy | statins monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 52 weeks)
1 | randomised trial | very serious^1^ | no serious inconsistency^2^ | serious^1^ | very serious^1^ | reporting bias^1^ | 2/78 (2.6%) | 1/71 (1.4%) | OR 1.84 (0.16 to 20.76) | 11 more per 1000 (from 12 fewer to 215 more) | VERY LOW | CRITICAL
Vascular death (follow-up 12 weeks)
1 | randomised trial | very serious^3^ | no serious inconsistency^2^ | serious^3^ | very serious^3^ | reporting bias^3^ | 0/27 (0%) | 0/27 (0%) | - | - | VERY LOW | CRITICAL
Participants reaching ATPIII LDL-c goals (follow-up 16 weeks)
1 | randomised trial | very serious^4^ | no serious inconsistency | serious^4^ | very serious^5^ | reporting bias^4^ | 21/32 (65.6%) | 19/34 (55.9%) | OR 1.51 (0.56 to 4.08) | 185 more per 1000 (from 205 fewer to 699 more) | VERY LOW | IMPORTANT

1 Single study comparing mixed statins in both arms, with adequate allocation concealment and double-blind procedure, no intention-to-treat analysis reported, long-term follow-up, and 3 deaths196

2 All participants had established vascular diseases

3 Single study comparing mixed statins in both arms, with unclear allocation concealment and double-blind procedure, no intention-to-treat analysis reported, short-term follow-up, and reporting no deaths197

4 One 16 week trial comparing different statins and different doses was included.49 This trial described an unclear allocation concealment, unclear double-blind procedure, and no intention-to-treat analysis.49

5 Wide confidence interval.

Table H-18

GRADE: Niacin-statin combination therapy versus statin monotherapy in participants with established vascular disease

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Niacin-statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 52 weeks)
1 | randomised trial | no serious limitations^1^ | no serious inconsistency | serious^1^ | very serious^1^ | reporting bias^1^ | 2/78 (2.6%) | 1/71 (1.4%) | OR 1.84 (0.16 to 20.76) | 11 more per 1000 (from 12 fewer to 215 more) | VERY LOW | CRITICAL
Vascular death (follow-up 12 weeks)
1 | randomised trial | very serious^2^ | no serious inconsistency | serious^2^ | very serious^2^ | reporting bias^2^ | 0/27 (0%) | 0/27 (0%) | - | - | VERY LOW | CRITICAL
Participants reaching ATPIII LDL-c goals (follow-up 16 weeks)
1 | randomised trial | very serious^3^ | no serious inconsistency | serious^3^ | very serious^4^ | reporting bias^3^ | 21/32 (65.6%) | 19/34 (55.9%) | OR 1.51 (0.56 to 4.08) | 185 more per 1000 (from 205 fewer to 699 more) | VERY LOW | IMPORTANT

1 One 52 week trial comparing mixed statins in both arms, reported 3 deaths.196 The trial reported an adequate allocation concealment and appropriate double-blind procedure, and did not perform an intention-to-treat analysis.196

2 One 12 week trial comparing mixed statins in both arms, with unclear allocation concealment, unclear double-blind procedure, and no description of intention-to-treat analysis reported no vascular death.197

3 One 16 week trial comparing different statins and different doses was included.49 This trial described an unclear allocation concealment, unclear double-blind procedure, and no intention-to-treat analysis.49

4 Wide confidence interval.

Table H-19

GRADE : Niacin-statin combination therapy versus statin monotherapy in all participants followed for more than 24 weeks

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Niacin-Statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 24–52 weeks)
4 | randomised trial | serious 1 | serious1,2 | serious 1 | serious^3^ | reporting bias^1^ | 3/595 (0.5%) | 2/365 (0.5%) | OR 1.08 (0.17 to 6.72) | 0 more per 1000 (from -4 fewer to 28 more) | VERY LOW | CRITICAL
Vascular death (followup 28 weeks)
1 | randomised trial | very serious^4^ | no serious inconsistency | serious^4^ | very serious4,3 | reporting bias^4^ | 1/114 (0.9%) | 1/61 (1.6%) | OR 0.53 (0.03 to 8.64) | 7 fewer per 1000 (from 16 fewer to 108 more) | VERY LOW | CRITICAL
Serious Adverse Events (follow-up 24–28 weeks)
3 | randomised trial | serious 5 | serious 5 | serious 5 | serious^3^ | reporting bias^5^ | 6/517 (1.2%) | 3/294 (1%) | OR 1.00 (0.26 to 3.86) | 0 fewer per 1000 (from 7 fewer to 28 more) | VERY LOW | CRITICAL
Participants reaching ATPIII LDL-c goals - not measured
0 | - | - | - | - | - | none | - | - | - | - | | IMPORTANT

1 Four 24–52 week trials comparing different statins and different statin doses reported this outcome. 105,150,171,196 Three trials reported an adequate allocation concealment,105,171,196 two had an appropriate double-blind procedure, 105,196 and intention-to-treat analysis was not performed.

2 In one study participants were diagnosed with coronary artery disease and LDL-c < 130 mg/dL,196 participants in the second trial had hyperlipidemia and were statin naive.105

3 Wide confidence interval.

4 One included trial comparing same dose of lovastatin in both arms, reported an unclear allocation concealment, an appropriate double-blind procedure and performed intention-to-treat analysis.128

5 Three 24–28 week trials comparing different statins and different statin doses reported 9 SAEs during follow up.105,150,171 Two trials described an adequate allocation concealment and an appropriate double-blind procedure,105,171 none of the trials performed an intention-to-treat analysis.

Table H-20

GRADE: Niacin -statin combination therapy versus statin monotherapy in all participants

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Niacin-statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 17–52 weeks 1 )
6 | randomised trial | serious1,2 | serious^2^ | serious^2^ | very serious^2^ | reporting bias^2^ | 3/755 (0.4%) | 2/458 (0.4%) | OR 1.08 (0.17 to 6.72) | 0 more per 1000 (from 3 fewer to 22 more) | VERY LOW | CRITICAL
Vascular death (follow-up 12–28 weeks)
2 | randomised trial | serious^3^ | serious^3^ | serious^3^ | very serious3,4 | reporting bias^3^ | 1/141 (0.7%) | 1/88 (1.1%) | OR 0.53 (0.03 to 8.64) | 5 fewer per 1000 (from 11 fewer to 77 more) | VERY LOW | CRITICAL
Serious Adverse Events (all trials) (follow-up 17–28 weeks)
5 | randomised trial | serious^5^ | serious5,6 | serious5,6 | serious^4^ | reporting bias^5^ | 12/677 (1.8%) | 4/387 (1%) | OR 1.29 (0.44 to 3.80) | 3 more per 1000 (from 6 fewer to 27 more) | VERY LOW | CRITICAL
Participants reaching ATPIII LDL-c goals (follow-up mean 16 weeks)
1 | randomised trial | very serious^7^ | very serious7,8 | serious7,8 | very serious7,8 | reporting bias^7^ | 78/105 (74.3%) | 78/117 (66.7%) | not pooled | not pooled | VERY LOW | IMPORTANT

1 Only the two long-term studies contributed data to the pooled analysis.105,196

2 Six 17–52 week trials comparing different statins and different statin doses reported this outcome.104,105,150,170,171,196 Four reported no events.104,150,170,171 Two long-term trials reported 5 deaths.105,196. Four trials described an adequate allocation concealment,104,105,171,196 3 reported an appropriate double-blind procedure,104,105,196 and none performed intention-to-treat analysis.

3 Two trials comparing different statins and different statin doses were included,128,197 one trial reported no vascular death.197 Both trials reported an unclear allocation concealment, one long-term trial reported an appropriate double-blind procedure and performed intention-to-treat analysis.128

4 Wide confidence interval.

5 Five 17–28 week trials comparing different statins and different statin doses were included.104,105,150,171,260 Three trials described an adequate allocation concealment, adequate double-blind procedure,104,105,171 no trial performed an intention-to-treat analysis.

6 Participants with mixed risk.

7 One 16 week trial was included.49 This trial described an unclear allocation concealment, unclear double-blind procedure, and no intention-to-treat analysis.49

8 Data is provided in four arms of the same trial comparing different statins and different statin doses in combination and monotherapy, but data was not pooled because of with significant heterogeneity (I-squared = 63%)

## GRADE: BAS Plus Statin Therapy Compared With Statin Monotherapy

Table H-21

GRADE: BAS-statin combination therapy versus statin monotherapy in participants requiring intensive lipid-lowering therapy

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | BAS-statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All-cause mortality - not measured
0 | - | - | - | - | - | none | - | - | - | - | | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | none | - | - | - | - | | CRITICAL
Participants reaching ATP III LDL-c targets (follow-up 12 weeks)
1 | randomised trial | very serious^1^ | no serious inconsistency | serious^1^ | no serious imprecision | reporting bias 1 | 13/28 (46.4%) | 5/31 (16.1%) | OR 4.51 (1.34 to 15.1) | 348 more per 1000 (from 46 more to 734 more) | VERY LOW | IMPORTANT

1 One trial comparing same dose of pravastatin in both arms was included. The trial reported unclear allocation concealment, no double-blind, no intention-to-treat analysis; short-term follow-up, and small sample size.108 All participants on the trial required lipid lowering therapy because of established vascular diseases.

Table H-22

GRADE: BAS-statin combination therapy versus statin monotherapy in all participants followed for more than 24 weeks

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | BAS-statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 24 weeks)
1 | randomised trial | very serious^1^ | no serious inconsistency | serious^1^ | very serious^1^ | reporting bias^1^ | 0/73 (0%) | 1/77 (1.3%) | OR 0.35 (0.01 to 8.9) | 8 fewer per 1000 (from 51 fewer to 119 more) | VERY LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | None | - | - | - | - | | CRITICAL
Serious Adverse Events (follow-up 30 weeks)
1 | randomised trial | very serious^2^ | no serious inconsistency | serious^2^ | very serious^2^ | reporting bias^2^ | 1/44 (2.3%) | 5/92 (5.4%) | OR 0.40 (0.05 to 3.6) | 32 fewer per 1000 (from 51 fewer to 119 more) | VERY LOW | CRITICAL
Participants reaching ATP III LDL-c targets - not measured
0 | - | - | - | - | - | None | - | - | - | - | | IMPORTANT

1 One 24 week trial comparing same dose of fluvastatin in both arms, reported one death.52 This trial described an unclear allocation concealment, unclear double-blind procedure and no intention-to-treat analysis was performed.52

2 One 30 week trial comparing different statins reported six SAEs.198 This trial described an unclear allocation concealment, unclear double-blind procedure and no intention-to-treat analysis was performed.198

Table H-23

GRADE: BAS-statin combination therapy versus statin monotherapy in all participants

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | BAS-statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 4–24 weeks)
3 | randomised trial | very serious^1^ | serious^1^ | serious^1^ | very serious^2^ | reporting bias^1^ | 1/195 (0.5%) | 1/178 (0.6%) | OR 1.07 (0.11 to 10.51) | 0 more per 1000 (from -5 fewer to 54 more) | VERY LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | None | - | - | - | - | | CRITICAL
Serious Adverse Events (follow-up 6–30 weeks)
2 | randomised trial | serious^3^ | serious^3^ | serious^3^ | very serious^3^ | reporting bias3,4 | 1/112 (0.9%) | 6/166 (3.6%) | OR 0.39 (0.06 to 2.36) | 22 fewer per 1000 (from 34 fewer to 45 more) | VERY LOW | CRITICAL
Participants reaching ATPIII LDL-c goals (follow-up 12 weeks)
1 | randomised trial | very serious^5^ | no serious inconsistency | serious^5^ | no serious imprecision | reporting bias 4 | 13/28 (46.4%) | 5/31 (16.1%) | OR 4.51 (1.34 to 15.1) | 348 more per 1000 (from 46 more to 734 more) | VERY LOW | IMPORTANT

1 Three trials comparing different statins and different statin doses were included.52,172,185 One trial reported no deaths during a 4 week follow up of 76 participants,185 and a single long term trial reported one death.52 One trial described adequate allocation concealment and appropriate double-blind procedure.172 None of the trials performed an intention-to-treat analysis.

2 Wide confidence interval.

3 Two 6–30 week trials comparing different statins and different statin doses reported 7 SAEs.172,198 One reported appropriate allocation concealment and appropriate double-blind procedure.172 None reported intention-to-treat analysis.

4 Results provided in only one out of 17 included trials

5 One trial comparing same dose of pravastatin in both arms was included. The trial reported unclear allocation concealment, no double-blind, no intention-to-treat analysis; short-term follow-up, and small sample size.108 All participants on the trial required lipid lowering therapy because of established vascular diseases.

## GRADE: Omega-3 Fatty Acid Plus Statin Therapy Compared With Statin Monotherapy

Table H-24

GRADE: statin plus Omega-3 therapy versus statin monotherapy, in all participants

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Omega- statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 5–240 weeks)
3 | randomised trial | No serious limitations^1^ | Serious^1^ | Serious^1^ | no serious imprecision | reporting bias 1 | 286/9469 (3%) | 265/9471 (2.8%) | OR 1.08 (0.91 to 1.28) | 2 more per 1000 (from 2 fewer to 8 more) | VERY LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | none | - | - | - | - | | CRITICAL
Serious Adverse Events (follow-up 8 weeks)
1 | randomised trial | serious^2^ | no serious inconsistency | serious^2^ | very serious2,3 | reporting bias^2^ | 4/122 (3.3%) | 1/132 (0.8%) | OR 4.44 (0.49 to 40.29) | 27 more per 1000 (from 4 fewer to 238 more) | VERY LOW | CRITICAL
Participants reaching ATPIII LDL-c goals - not measured
0 | - | - | - | - | - | none | - | - | - | - | | IMPORTANT

1 Three 5–240 week trials comparing different statins and different statin doses were included,141,177,180 two short term trials reported no deaths.177,180 Two trials reported an adequate allocation concealment,141,180 two reported appropriate double-blind procedure,177,180 and one performed intention-to-treat analysis.141

2 One 8 week trial comparing same dose of simvastatin in both arms was included.180 This trial described an adequate allocation concealment and appropriate double-blind procedure, no intention-to-treat analysis was reported.180

3 Results based on a single-trial with wide confidence interval

Table H-25

GRADE: Omega-3-statin combination therapy versus statin monotherapy, in participants of Asian origin (long-term duration)

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Omega- statin combination therapy | statin monotherapy | Relative (95% CI) | Absolute | Quality | Importance
All cause mortality (follow-up 240 weeks)
1 | randomised trial | no serious limitations^1^ | no serious inconsistency | serious 1 | no serious imprecision | reporting bias^1^ | 286/9326 (3.1%) | 265/9319 (2.8%) | OR 1.08 (0.91 to 1.28) | 2 more per 1000 (from 2 fewer to 8 more) | LOW | CRITICAL
Vascular death - not measured
0 | - | - | - | - | - | none | - | - | - | - | | CRITICAL
Participants reaching ATPIII LDL-c goals - not measured
0 | - | - | - | - | - | none | - | - | - | - | | IMPORTANT

1 One long-term trial comparing mixed statins, with adequate allocation concealment and intention-to-treat analysis was described, no double-blind procedure reported.141 All participants in the trial were of Asian origin.