# Appendix G Forest and Funnel Plots

## Forest and Funnel Plots: Ezetimibe - Statin Combination Therapy Versus Statin Monotherapy

Figure G-1

Forest and funnel plots of all-cause mortality for ezetimibe plus statin therapy compared with statin monotherapy in all participants

Figure G-2

Forest and funnel plots of all-cause mortality for ezetimibe plus statin therapy compared with statin monotherapy in all participants in trials with adequate allocation concealment

Figure G-3

Forest and funnel plots of all-cause mortality for ezetimibe plus statin therapy compared with statin monotherapy in participants requiring intensive lipid lowering therapy

Figure G-4

Forest plot of all-cause mortality for ezetimibe plus statin therapy compared with statin monotherapy in participants requiring intensive lipid lowering, trials with adequate allocation concealment

Figure G-5

Forest plot of vascular death for ezetimibe plus statin therapy compared with statin monotherapy in all participants

Figure G-6

Forest and funnel plots of serious adverse events for ezetimibe plus statin therapy compared with statin monotherapy in trials 24 weeks or more duration

Figure G-7

Forest and funnel plots of serious adverse events for ezetimibe plus statin therapy compared with statin monotherapy in all participants

Figure G-8

Forest and funnel plots of participants attaining ATP III LDL-c targets for ezetimibe plus statin therapy compared with statin monotherapy in all participants

Figure G-9

Forest and funnel plots of participants attaining ATP III LDL-c targets for ezetimibe plus statin therapy compared with statin monotherapy, in participants requiring intensive lipid lowering therapy

Figure G-10

Forest plot of achievement of ATP III LDL-c targets for lower dose ezetimibe plus simvastatin therapy compared with higher dose simvastatin monotherapy, in participants requiring intensive lipid lowering therapy

Figure G-11

Forest plot of achievement of ATP III LDL-c targets for lower dose ezetimibe plus simvastatin therapy compared with higher dose simvastatin monotherapy in participants requiring intensive lipid lowering therapy, in studies with fixed doses or fixed titration of doses

Figure G-12

Forest and funnel plots of LDL-c difference in mean percentage change from baseline for ezetimibe plus statin therapy compared with statin monotherapy in all participants

Figure G-13

Forest and funnel plots of LDL-c difference in mean percentage change from baseline for ezetimibe plus lower dose simvastatin therapy compared with higher dose simvastatin monotherapy in all participants

Figure G-14

Forest and funnel plots of LDL-c difference in mean percentage change from baseline for ezetimibe plus statin therapy compared with statin monotherapy in participants requiring intensive lipid lowering therapy

Figure G-15

Forest and funnel plots of LDL-c difference in mean percentage change from baseline for ezetimibe plus lower dose simvastatin therapy compared with higher dose simvastatin monotherapy in participants requiring intensive lipid lowering therapy

Figure G-16

Funnel plot of HDL-c difference in mean percentage change from baseline for ezetimibe plus statin therapy compared with statin monotherapy in all participants

Figure G-17

Funnel plot of HDL-c difference in mean percentage change from baseline for ezetimibe plus lower dose simvastatin therapy compared with higher simvastatin monotherapy in all participants, in trials with fixed doses or fixed titration of doses

Figure G-18

Funnel plot of HDL-c difference in mean percentage change from baseline for ezetimibe plus statin therapy compared with statin monotherapy in participants requiring intensive lipid lowering

Figure G-19

Funnel plot of difference in total cholesterol:HDL-c ratio percentage change from baseline for ezetimibe plus statin therapy compared with statin monotherapy in all participants

Figure G-20

Funnel plot of total cholesterol:HDL-c ratio difference in mean percentage change from baseline for ezetimibe plus lower dose simvastatin therapy compared with higher simvastatin monotherapy in all participants, in studies with fixed doses or fixed titration of doses

Figure G-21

Funnel plots of total cholesterol:HDL-c (ratio) difference in mean percentage change from baseline for ezetimibe plus statin compared with statin monotherapy in participants requiring intensive lipid lowering therapy

Figure G-22

Funnel plot of treatment adherence, for ezetimibe plus statin therapy compared with statin monotherapy in all participants

Figure G-23

Funnel plot of proportion of participants with at least one adverse event, for ezetimibe plus statin therapy compared with statin monotherapy in all participants

Figure G-24

Funnel plot of proportion of participants withdrawing from treatment due to an adverse event, for ezetimibe plus statin therapy compared with statin monotherapy in all participants

Figure G-25

Funnel plot of proportion of participants with AST and/or ALT above 3 times the upper limit of normal, and/or hepatitis, for ezetimibe plus statin therapy compared with statin monotherapy in all participants

Figure G-26

Funnel plot of proportion of participants with AST and/or ALT above 3 times the upper limit of normal, and/or hepatitis, for ezetimibe plus lower dose simvastatin therapy compared with higher dose simvastatin monotherapy in all participants

Figure G-27

Funnel plot of proportion of participants with AST and/or ALT above 3 times the upper limit of normal, and/or hepatitis, for ezetimibe plus lower dose simvastatin therapy compared with higher dose simvastatin monotherapy in all participants, in studies with fixed doses or fixed titration of doses

Figure G-28

Funnel plot of proportion of participants experiencing myalgia, for ezetimibe plus statin therapy compared with statin monotherapy in all participants

Figure G-29

Funnel plot of proportion of participants with CPK above 10 times the upper limit of normal, for ezetimibe plus statin therapy compared with statin monotherapy in all participants

Figure G-30

Forest plot of all-cause mortality for ezetimibe plus statin therapy compared with statin monotherapy in participants with diabetes mellitus

Figure G-31

Forest plot of all-cause mortality for ezetimibe plus statin therapy compared with statin monotherapy in participants with established vascular disease

Figure G-32

Forest and funnel plots of achievement of ATP III LDL-c targets for ezetimibe plus statin therapy compared with statin monotherapy in participants with diabetes mellitus

Figure G-33

Forest and funnel plots of achievement of ATP III LDL-c targets for ezetimibe plus statin therapy compared with statin monotherapy in participants with established vascular disease

Figure G-34

Forest plots of achievement of ATP III LDL-c targets for ezetimibe plus statin therapy compared with statin monotherapy in female participants

Figure G-35

Forest plot of LDL-c difference in mean percentage change from baseline, for ezetimibe plus statin therapy compared with statin monotherapy in participants with baseline LDL-c above 190 mg/dL

Figure G-36

Forest and funnel plots of LDL-c difference in mean percentage change from baseline, for ezetimibe plus statin therapy compared with statin monotherapy in participants with diabetes mellitus

Figure G-37

Forest plot of LDL-c difference in mean percentage change from baseline, for ezetimibe plus statin therapy compared with statin monotherapy in participants with established vascular disease

Figure G-38

Forest plot of LDL-c difference in mean percentage change from baseline, for ezetimibe plus statin therapy compared with statin monotherapy in participants of African descent

Figure G-39

Forest plot of LDL-c difference in mean percentage change from baseline, for ezetimibe plus statin therapy compared with statin monotherapy in female participants

Figure G-40

Forest plot of LDL-c difference in mean percentage change from baseline, for ezetimibe plus lower dose simvastatin therapy compared with higher dose simvastatin monotherapy in female participants

Figure G-41

Funnel plot of HDL-c difference in mean percentage change from baseline, for ezetimibe plus statin therapy compared with statin monotherapy in participants with diabetes mellitus

Figure G-42

Funnel plot of total cholesterol:HDL-c ratio difference in mean percentage change from baseline, for ezetimibe plus statin therapy compared with statin monotherapy in participants with diabetes mellitus

Figure G-43

Funnel plot of total non-HDL-c ratio difference in mean percentage change from baseline, for ezetimibe plus statin therapy compared with statin monotherapy in participants with diabetes mellitus

## Forest and Funnel Plots: Fibrate - Statin Combination Therapy versus Statin Monotherapy

Figure G-44

Forest plot of all-cause mortality for fibrate-statin therapy compared with statin monotherapy, in all participants

Figure G-45

Forest plot of achievement of ATP III LDL-c targets, for fibrate-statin therapy compared with statin monotherapy, in all participants, who required intensive lipid lowering therapy due to diabetes mellitus

Figure G-46

Forest plot of difference in LDL-c mean percentage change from baseline for fibrate-statin therapy compared with statin monotherapy, in all participants

Figure G-47

Forest plot of difference in LDL-c mean percentage change from baseline for fibrate-statin therapy compared with statin monotherapy, in participants requiring intensive lipid lowering therapy

Figure G-48

Forest plot of difference in LDL-c mean percentage change from baseline for fibrate-statin therapy compared with statin monotherapy, in participants with diabetes mellitus

Figure G-49

Funnel plot of incidence of participants with myalgia, for fibrate-statin therapy compared with statin monotherapy, in all participants

## Forest and Funnel Plots: Niacin - Statin Combination Therapy Versus Statin Monotherapy

Figure G-50

Forest plot of all-cause mortality for niacin plus statin therapy compared with statin monotherapy, in all participants, in all trials with followup of 24 weeks or longer, and in all trials with adequate allocation concealment

Figure G-51

Forest plot of serious adverse events for niacin plus statin therapy compared with statin monotherapy, in all participants

Figure G-52

Forest plot of serious adverse events for niacin plus statin therapy compared with statin monotherapy, in all participants, and in all trials with a followup of 24 weeks or longer

Figure G-53

Forest and funnel plots of difference in LDL-c mean percentage change from baseline for niacin plus statin therapy compared with statin monotherapy, in all participants

Figure G-54

Funnel plots of difference in HDL-c mean percentage change from baseline for niacin plus statin therapy compared with statin monotherapy, in all participants

Figure G-55

Funnel plot of incidence of participants experiencing an adverse event, for niacin plus statin therapy compared with statin monotherapy, in all participants

Figure G-56

Funnel plot of incidence of withdrawal from treatment due to an adverse event, for niacin plus statin therapy compared with statin monotherapy, in all participants

## Forest and Funnel Plots: Bile Acid Sequestrant (BAS) - Statin Combination Therapy versus Statin Monotherapy

Figure G-57

Forest plot of all-cause mortality for BAS plus statin therapy compared with statin monotherapy, in all participants

Figure G-58

Forest plot of serious adverse events for BAS plus statin therapy compared with statin monotherapy, in all participants

Figure G-59

Forest and funnel plots with Egger’s regression test, of difference in LDL-c mean percentage change from baseline, for BAS plus statin therapy compared with statin monotherapy in all participants

Figure G-60

Forest plot of difference in LDL-c mean percentage change from baseline for BAS plus statin therapy compared with statin monotherapy, in participants requiring intensive lipid lowering therapy

Figure G-61

Forest plot of difference in LDL-c mean percentage change from baseline, for BAS plus statin therapy compared with statin monotherapy, in participants with LDL-c above 190 mg/dL

Figure G-62

Funnel plot of treatment adherence on participants BAS plus statin therapy compared with statin monotherapy, in all participants

Figure G-63

Funnel plot of participants with adverse events for BAS plus statin therapy compared with statin monotherapy, in all participants

Figure G-64

Funnel plot of participants withdrawing from treatment due to adverse events for BAS plus statin therapy compared with statin monotherapy, in all participants

## Forest Plot: Omega-3 Fatty Acid - Statin Combination Therapy versus Statin Monotherapy

Figure G-65

Forest plot of difference in LDL-c mean percentage change from baseline for omega-3 fatty acid plus statin therapy compared with statin monotherapy, in all participants