# Appendix F Included Evidence

This appendix contains details of all trial treatment groups included in syntheses.

Abbreviations
1° HC: primary hypercholesterolemia
AAC: adequate allocation concealment
ALT: alanine transaminase
AST: aspartate transaminase
ATP III: Adult Treatment Panel III (of the National Cholesterol Education Program)
C-amine: cholestyramine
C-lam: colesevelam
C-pol: colestipol
CAD: coronary artery disease
CHD: coronary heart disease
combo: combination therapy
CPK: creatine phosphokinase
DM: diabetes mellitus
Ext Rls: extended release (niacin)
FHC: familial hypercholesterolemia
HC: hypercholesterolemia
HDL-c: high density lipoprotein cholesterol
Imm Rls: immediate release (niacin)
ITTA: intention to treat analysis
LDL-c: low density lipoprotein cholesterol
mono: monotherapy
N: number
Slow Rls: slow release (niacin)
T2DM: type 2 diabetes mellitus
wk: week

## Included Evidence for Ezetimibe plus Statin Therapy Compared With Statin Monotherapy

This set of tables present all the randomized controlled trial data employed in evidence synthesis. The data falls into one or more of the following categories for the outcomes:

- All statins, all doses, all clinical populations. These are clinically diverse trials, to investigate a common drug effect. This category includes analyses for all types of statin, comparing similar or closest possible statin doses in the two investigated interventions (i.e. statin-ezetimibe combination therapy, and statin monotherapy). It includes trials of any duration – short-term trials of less than 24 weeks duration, and long-term trials of 24 weeks or longer follow-up. It includes trials with inadequate, unclear or adequate allocation concealment.
- All statins, lower versus higher doses, all clinical populations. These are clinically diverse trials to investigate a potential advantage of higher dose statin monotherapy over combination therapy with a lower dose of the same statin plus ezetimibe. In other words, this category includes statin specific analyses comparing lower doses of statin-ezetimibe combination with a higher dose of the same statin monotherapy. It includes trials of any duration – short-term trials of less than 24 weeks duration, and long-term trials of 24 weeks or longer follow-up. It includes trials with inadequate, unclear or adequate allocation concealment.
- All statins, all doses, intensive lipid lowering populations and clinical subgroups. These are a variety of relatively clinically homogenous populations, to investigate effects among specific groups within clinical diversity. This category includes statin non-specific analyses comparing similar or closest possible statin doses in the two investigated interventions (i.e. statin-ezetimibe combination, and statin monotherapy). It includes trials of any duration – short-term trials of less than 24 weeks duration, and long-term trials of 24 weeks or longer follow-up. It includes trials with inadequate, unclear or adequate allocation concealment.
- All statins, lower versus higher doses, intensive lipid lowering populations and clinical subgroups. These are a variety of relatively clinically homogenous populations, to investigate potential advantage of higher dose statin monotherapy over combination therapy with a lower dose of the same statin plus ezetimibe, among diverse clinical subgroups. This category includes statin specific analyses comparing lower doses of statin-ezetimibe combination therapy with a higher dose of the same statin monotherapy. It includes trials of any duration – short-term trials of less than 24 weeks duration, and long-term trials of 24 weeks or longer follow-up. It includes trials with inadequate, unclear or adequate allocation concealment.
- Note, when all the trial data in a category is included as a whole in a prior category, then that category is not reported in the appendix. Also adverse event outcomes were assessed in all trial populations and not specific clinical groups. Non-HDL-c and triglycerides were investigated in the diabetes mellitus subgroup only – no evidence was available for triglycerides

Table F-1

Longer-term outcomes (clinical outcomes, serious adverse events and cancer) using ezetimibe plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Trial Baseline LDL-c (mg/dL) | Combo/mono: number of participants with events Odds ratio (95% CI) | AAC | Jadad Score | ITTA
All-cause Mortality: all statins, all doses, all clinical populations
Ballantyne (2003)126 Ezetimibe Study Group International Pharm. Fund Multicentre | 1° HC, heterogeneous 10-year CHD risk estimates | Atorvastatin 80 | 201 | Atorvastatin 80 | 45 | 52 | 183 | 0/0 | unclear | 2 | No
Goldberg (2004)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 539 | Simvastatin 20–80 | 229 | 48 | 175 | 0/0 | Adequate | 5 | No
Landray (2006)166 UK-HARP-II Europe Pharm. Fund Multicentre | Participants with renal disease and without definitive indication for cholesterol lowering | Simvastatin 20 | 98 | Simvastatin 20 | 102 | 24 | 119 | 3/0 7.86 (0.81, 76.45) | Adequate | 2 | Yes
Gaudiani (2005)121 North America Pharm. Fund Multicentre | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 104 | Simvastatin 40 | 110 | 24 | 93 | 0/0 | unclear | 3 | No
Rodney (2006)111 Pharm. Fund Multicentre | African descent, 1° HC | Simvastatin 20 | 124 | Simvastatin 20 | 123 | 12 | 176 | 0/0 | Adequate | 5 | No
Melani (2003)127 Ezetimibe Study Group North America Pharm. Fund Multicentre | 1° HC, heterogeneous 10-year CHD risk estimates | Pravastatin 10–40 | 184 | Pravastatin 10–40 | 192 | 12 | 178 | 0/0 | Adequate | 4 | Yes
Kerzner (2003)129 Ezetimibe Study Group North America Pharm. Fund Multicentre | 1° HC, heterogeneous 10-year CHD risk estimates | Lovastatin 10–40 | 192 | Lovastatin 10–40 | 220 | 12 | 179 | 0/0 | unclear | 3 | Yes
Constance (2007)194 International Pharm. fund | Participants with T2DM on low dose atorvastatin | Simvastatin 20–40 | 442 | Atorvastatin 20 | 219 | 8 | 94 | 1/1 0.47 (0.02, 8.88) | Adequate | 3 | No
Farnier (2005)114 International Pharm. Fund Multicentre | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 181 | Simvastatin 10–20 | 191 | 6 | 123 | 0/0 | unclear | 5 | No
Cruz-Fernandez (2005)115 International Pharm. Fund Multicentre | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 220 | Atorvastatin 10–20 | 230 | 6 | 122 | 0/1 0.14 (0.00, 7.13) | unclear | 4 | No
Brohet (2005)116 Europe Pharm. Fund Multicentre | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 208 | Simvastatin 10–20 | 210 | 6 | 123 | 0/0 | unclear | 5 | No
Pearson (2005)117 EASE North America Pharm. Fund Multicentre | Participants not meeting ATP III target LDL-c despite statin therapy | Mixed | 1965 | Mixed | 992 | 6 | 129 | 0/0 | Adequate | 4 | No
Blagden (2007)140 Europe Pharm. Fund Multicentre | Participants with CAD, statin naïve | Atorvastatin 10 | 72 | Atorvastatin 10 | 76 | 6 | 157 | 0/0 | unclear | 4 | Yes
Ballantyne (2007)142 Europe Pharm. Fund Multicentre | CHD and risk equivalent | Rosuvastatin 40 | 238 | Rosuvastatin 40 | 230 | 6 | 190 | 1/0 7.14 (0.14, 360.28) | unclear | 1 | No
Patel (2006)143 Europe Pharm. Fund Multicentre | Participants with CAD not on recent lipid lowering drug treatment | Simvastatin 20 | 76 | Simvastatin 20 | 75 | 6 | 160 | 0/1 0.13 (0.00, 6.73) | unclear | 3 | No
Goldberg (2006)144 VYTAL North America Pharm. Fund Multicentre | T2DM, hemoglobin A- 1c < 8.5% and LDL-c > 100 mg/dL | Simvastatin 20–40 | 494 | Atorvastatin 10–40 | 732 | 6 | 145 | 0/1 0.19 (0.00, 10.19) | Adequate | 3 | No
Catapano (2006_1)193 North America Pharm. Fund Multicentre | Hypercholesterolemia, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 492 | Rosuvastatin 10 | 492 | 6 | 173 | 0/0 | Adequate | 3 | No
Catapano (2006_2)193 North America Pharm. Fund Multicentre | Hypercholesterolemia, heterogeneous 10- year CHD risk estimates | Simvastatin 40 | 493 | Rosuvastatin 20 | 495 | 6 | 173 | 0/0 | Adequate | 3 | No
Catapano (2006_3)193 North America Pharm. Fund Multicentre | Hypercholesterolemia, heterogeneous 10- year CHD risk estimates | Simvastatin 80 | 493 | Rosuvastatin 40 | 494 | 6 | 173 | 0/0 | Adequate | 3 | No
Reckless (2008)149 INFORCE International Pharm. Fund Multicentre | CHD patients on previous stable statin dose | Simvastatin 40 | 213 | Double the previous (mixed) statin dose | 211 | 12 | 92.5 | 4/4 0.99 (0.24, 4.01) | Adequate | 2 | No
Roeters van Lennep (2008)151 EASEGO Europe Pharm. Fund Multicentre | CHD and/or controlled type II DM patients not on target LDL-c despite prior low dose simvastatin or atorvastatin therapy | Simvastatin 40 | 178 | Simvastatin 40 or Atorvastatin 20 | 189 | 12 | 115 | 0/0 | Unclear | 3 | No
Gouni- Berthold (2008)110 Europe Pharm. Fund Single | Healthy males with LDL-c < 190 mg/dL and < 60 years of age, previously not on lipid lowering treatment | Simvastatin 40 | 24 | Simvastatin 40 | 24 | 2 | 114.5 | 0/0 | Unclear | 2 | Yes
Conrad (2008)158 International Pharm. Fund Multicenter | Moderately high risk participants on atorvastatin 20 mg/day or statin naive and with LDL-c 100 mg/dL to <= 160 mg/dL | Atorvastatin 20 | 96 | Atorvastatin 40 | 98 | 6 | 119 | 0/0 | Adequate | 5 | No
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10-year CHD risk > 20% | Atorvastatin 40 | 286 | Atorvastatin 80 | 289 | 6 | 89 | 0/0 | Adequate | 5 | No
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 34 | Simvastatin 40 | 66 | 4 | 169 | 0/0 | Adequate | 5 | Yes
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants with DM not at LDL-c ATP III goal off lipid lowering treatment | Simvastatin 10–80 | 220 | Atorvastatin 10–80 | 206 | 6 | 178 | 0/1 0.13 (0.00, 6.39) | Adequate | 2 | No
All-cause Mortality: all statins, lower versus higher doses, all clinical populations
Conrad (2008)158 International Pharm. Fund Multicenter | Moderately high risk participants on atorvastatin 20 mg/day or statin naive and with LDL-c 100 mg/dL to <= 160 mg/dL | Atorvastatin 20 | 96 | Atorvastatin 40 | 98 | 6 | 119 | 0/0 | Adequate | 5 | No
Gaudiani (2005)121 North America Pharm. Fund Multicentre | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 104 | Simvastatin 40 | 110 | 24 | 93 | 0/0 | unclear | 3 | No
Roeters van Lennep (2008)151 EASEGO Europe Pharm. Fund Multicentre | CHD and/or controlled type II DM patients not on target LDL-c despite prior low dose simvastatin or atorvastatin therapy | Simvastatin 20 | 110 | Simvastatin 40 | 115 | 12 | 115 | 0/0 | Unclear | 3 | No
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 34 | Simvastatin 40 | 66 | 4 | 169 | 0/0 | Adequate | 5 | Yes
All-cause mortality: all statins, all doses, intensive lipid lowering populations and clinical subgroups
Farnier (2005)114 International Pharm. Fund Multicentre | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 181 | Simvastatin 10–20 | 191 | 6 | 123 | 0/0 | unclear | 5 | No
Cruz-Fernandez (2005)115 International Pharm. Fund Multicentre | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 220 | Atorvastatin 10–20 | 230 | 6 | 122 | 0/1 0.14 (0.00, 7.13) | unclear | 4 | No
Brohet (2005)116 Europe Pharm. Fund Multicentre | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 208 | Simvastatin 10–20 | 210 | 6 | 123 | 0/0 | unclear | 5 | No
Gaudiani (2005)121 North America Pharm. Fund Multicentre | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 104 | Simvastatin 40 | 110 | 24 | 93 | 0/0 | unclear | 3 | No
Blagden (2007)140 Europe Pharm. Fund Multicentre | Participants with CAD, statin naïve | Atorvastatin 10 | 72 | Atorvastatin 10 | 76 | 6 | 157 | 0/0 | unclear | 4 | Yes
Ballantyne (2007)142 Europe Pharm. Fund Multicentre | CHD and risk equivalent | Rosuvastatin 40 | 238 | Rosuvastatin 40 | 230 | 6 | 190 | 1/0 7.14 (0.14, 360.28) | unclear | 1 | No
Patel (2006)143 Europe Pharm. Fund Multicentre | Participants with CAD not on recent lipid lowering drug treatment | Simvastatin 20 | 76 | Simvastatin 20 | 75 | 6 | 160 | 0/1 0.13 (0.00, 6.73) | unclear | 3 | No
Goldberg (2006)144 VYTAL North America Pharm. Fund Multicentre | T2DM, hemoglobin A- 1c < 8.5% and LDL-c > 100 mg/dL | Simvastatin 20–40 | 494 | Atorvastatin 10–40 | 732 | 6 | 145 | 0/1 0.19 (0.00, 10.19) | Adequate | 3 | No
Constance (2007)194 International Pharm. fund | Participants with T2DM on low dose atorvastatin | Simvastatin 20–40 | 442 | Atorvastatin 20 | 219 | 8 | 94 | 1/1 0.47 (0.02, 8.88) | Adequate | 3 | No
Reckless (2008)149 INFORCE International Pharm. Fund Multicentre | CHD patients on previous stable statin dose | Simvastatin 40 | 213 | Double the previous (mixed) statin dose | 211 | 12 | 92.5 | 4/4 0.99 (0.24, 4.01) | Adequate | 2 | No
Roeters van Lennep (2008)151 EASEGO Europe Pharm. Fund Multicentre | CHD and/or controlled type II DM patients not on target LDL-c despite prior low dose simvastatin or atorvastatin therapy | Simvastatin 40 | 178 | Simvastatin 40 or Atorvastatin 20 | 189 | 12 | 115 | 0/0 | Unclear | 3 | No
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10-year CHD risk > 20% | Atorvastatin 40 | 286 | Atorvastatin 80 | 289 | 6 | 89 | 0/0 | Adequate | 5 | No
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants with DM not at LDL-c ATP III goal off lipid lowering treatment | Simvastatin 10–80 | 220 | Atorvastatin 10–80 | 206 | 6 | 178 | 0/1 0.13 (0.00, 6.39) | Adequate | 2 | No
Catapno (2006)193 North America Pharm. Fund Multicenter | Participants with DM | Simvastatin 20 | 190 | Rosuvastatin 10 | 185 | 6 | 173 | 0/0 | Adequate | 3 | No
Rodney (2006)111 Pharm. Fund Multicentre | African descent, 1° HC | Simvastatin 20 | 124 | Simvastatin 20 | 123 | 12 | 176 | 0/0 | Adequate | 5 | No
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 29 | Simvastatin 40 | 15 | 4 | 169 | 0/0 | Adequate | 5 | Yes
Reckless (2008)149 INFORCE International Pharm. Fund Multicentre | CHD patients on previous stable statin dose | Simvastatin 40 | 43 | Double the previous (mixed) statin dose | 41 | 12 | 92.5 | 1/1 0.95 (0.06, 15.75) | Adequate | 2 | No
All-cause mortality: all statins, lower versus higher doses, intensive lipid lowering populations and clinical subgroups
Gaudiani (2005)121 North America Pharm. Fund Multicentre | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 104 | Simvastatin 40 | 110 | 24 | 93 | 0/0 | unclear | 3 | No
Roeters van Lennep (2008)151 EASEGO Europe Pharm. Fund Multicentre | CHD and/or controlled type II DM patients not on target LDL-c despite prior low dose simvastatin or atorvastatin therapy | Simvastatin 20 | 110 | Simvastatin 40 | 115 | 12 | 115 | 0/0 | Unclear | 3 | No
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 29 | Simvastatin 40 | 15 | 4 | 169 | 0/0 | Adequate | 5 | Yes
Vascular Death: all statins, all doses, all clinical populations
Kastelein (2008)42 ENHANCE International Pharm. fund | FHC, LDL-c > 210 mg/dL | Simvastatin 80 | 357 | Simvastatin 80 | 363 | 96 | 318 | 2/1 1.98 (0.21, 19.14) | Adequate | 3 | No
Davidson (2002_1)130 Ezetimibe study group North America Pharm. Fund Multicentre | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10 | 61 | Simvastatin 10 | 61 | 12 | 179 | 0/0 | Adequate | 4 | No
Davidson (2002_2)130 Ezetimibe study group North America Pharm. Fund Multicentre | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 20 | 58 | Simvastatin 20 | 53 | 12 | 179 | 1/0 6.78 (0.13, 342.99) | Adequate | 4 | No
Davidson (2002_3)130 Ezetimibe study group North America Pharm. Fund Multicentre | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 40 | 68 | Simvastatin 40 | 60 | 12 | 179 | 0/0 | Adequate | 4 | No
Davidson (2002_4)130 Ezetimibe study group North America Pharm. Fund Multicentre | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 80 | 52 | Simvastatin 80 | 63 | 12 | 179 | 0/0 | Adequate | 4 | No
Vascular death: all statins, lower versus higher doses, all clinical populations
Davidson (2002_5)130 Ezetimibe study group North America Pharm. Fund Multicentre | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10 | 61 | Simvastatin 40 | 60 | 12 | 179 | 0/0 | Adequate | 4 | No
Davidson (2002_6)130 Ezetimibe study group North America Pharm. Fund Multicentre | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 20 | 58 | Simvastatin 80 | 63 | 12 | 179 | 1/0 8.05 (0.16, 407.27) | Adequate | 4 | No
Vascular death: all statins, all doses, intensive lipid lowering populations and clinical subgroups
Kastelein (2008)42 ENHANCE International Pharm. fund | FHC, LDL-c > 210 mg/dL | Simvastatin 80 | 357 | Simvastatin 80 | 363 | 96 | 318 | 2/1 1.98 (0.21, 19.14) | Adequate | 3 | No
Fatal Myocardial Infarction: all statins, all doses, all clinical populations
Ballantyne (2007)142 Europe Pharm. Fund Multicentre | CHD and risk equivalent | Rosuvastatin 40 | 238 | Rosuvastatin 40 | 230 | 6 | 190 | 1/0 7.14(0.14, 360.28) | unclear | 1 | No
Stein (2004)156 International Pharm. fund | Those with LDL >= 130 mg/dL despite diet and atorvastatin 10 mg/day | Atorvastatin 40 | 278 | Atorvastatin 80 | 290 | 14 | 186 | 0/1 0.14 (0.00, 7.11) | unclear | 3 | Yes
Reckless (2008)149 INFORCE International Pharm. Fund Multicentre | CHD patients on previous stable statin dose | Simvastatin 40 | 213 | Double doses of pervious statins (mixed) | 211 | 12 | 92.5 | 2/0 7.35 (0.46, 117.97) | Adequate | 2 | No
Any or unspecified myocardial infarction: all statins, all doses, all clinical populations
Reckless (2008)149 INFORCE International Pharm. Fund Multicentre | CHD patients on previous stable statin dose | Simvastatin 40 | 213 | Double doses of pervious statins (mixed) | 211 | 12 | 92.5 | 6/5 1.19 (0.36, 3.97) | Adequate | 2 | No
Stroke (ischemic and/or hemorrhagic)
Landray (2006)166 UK-HARP-II Europe Pharm. Fund Multicentre | Participants with renal disease and without definitive indication for cholesterol lowering | Simvastatin 20 | 98 | Simvastatin 20 | 102 | 24 | 119 | 1/0 7.70 (0.0.15, 388.20) | Adequate | 2 | Yes
Serious Adverse Events: all statins, all doses, all clinical populations
69 Rodney (2006)111 Pharm. Fund Multicentre | African descent, 1° HC | Simvastatin 20 | 124 | Simvastatin 20 | 123 | 12 | 176 | 2/1 2.00 (0.18, 22.35) | Adequate | 5 | No
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 221 | Atorvastatin 20 | 214 | 6 | 124 | 5/2 1.97 (0.18, 22.23) | unclear | 3 | No
Landray (2006)166 UK-HARP-II Europe Pharm. Fund Multicentre | Participants with renal disease and without definitive indication for cholesterol lowering | Simvastatin 20 | 102 | Simvastatin 20 | 101 | 24 | 119 | 36/25 1.66 (0.90, 3.04) | Adequate | 2 | Yes
Farnier (2005)114 International Pharm. Fund Multicentre | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 181 | Simvastatin 10–20 | 191 | 6 | 123 | 4/1 0.35 (0.01, 8.66) | unclear | 5 | No
Cruz-Fernandez (2005)115 International Pharm. Fund Multicentre | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 220 | Atorvastatin 10–20 | 230 | 6 | 122 | 3/4 4.29 (0.48, 38.78) | unclear | 4 | No
Brohet (2005)116 Europe Pharm. Fund Multicentre | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 208 | Simvastatin 10–20 | 210 | 6 | 123 | 5/0 11.38 (0.63, 207.10) | unclear | 5 | No
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants with DM not at LDL-c ATP III goal off lipid lowering treatment | Simvastatin 10–80 | 220 | Atorvastatin 10–80 | 206 | 6 | 178 | 3/6 0.46 (0.11, 1.87) | Adequate | 2 | No
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals | Simvastatin 80 | 296 | Simvastatin 80 | 57 | 48 | 136 | 43/13 0.58 (0.29, 1.16) | unclear | 3 | No
Gaudiani (2005)121 North America Pharm. Fund Multicentre | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 104 | Simvastatin 40 | 110 | 24 | 93 | 5/1 5.51 (0.63, 47.94) | unclear | 3 | No
Bays (2004)154 North America Pharm. Fund Multicentre | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 544 | Simvastatin 10–80 | 560 | 14–26 | 178 | 11/13 0.87 (0.39, 1.96) | Adequate | 5 | No
Stein (2004)156 International Pharm. fund | Those with LDL >= 130 mg/dL despite diet and atorvastatin 10 mg/day | Atorvastatin 40 | 305 | Atorvastatin 80 | 316 | 14 | 186 | 9/12 0.77 (0.32, 1.86) | unclear | 3 | Yes
Feldman (2004)47 North America Pharm. Fund Multicentre | Participants with CHD or risk equivalent | Simvastatin 10–40 | 457 | Simvastatin 40 | 253 | 23 | 169 | 27/12 1.26 (0.63, 2.53) | unclear | 2 | No
Goldberg (2004)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 539 | Simvastatin 20–80 | 229 | 48 | 175 | 28/6 2.04 (0.83, 4.99) | Adequate | 45 | No
Ballantyne (2003)126 Ezetimibe Study Group International Pharm. Fund Multicentre | 1° HC, heterogeneous 10-year CHD risk estimates | Atorvastatin 80 | 201 | Atorvastatin 80 | 45 | 52 | 183 | 17/5 0.74 (0.26, 2.12) | unclear | 2 | No
Davidson (2002)130 Ezetimibe study group North America Pharm. Fund Multicentre | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 87 | Simvastatin 10–80 | 22 | 48 | 179 | 8/4 0.46 (0.12, 1.68) | Adequate | 4 | No
Blagden (2007)140 Europe Pharm. Fund Multicentre | Participants with CAD, statin naïve | Atorvastatin 10 | 72 | Atorvastatin 10 | 76 | 6 | 157 | 0/1 2.45 (0.47, 12.79) | unclear | 4 | Yes
Ballantyne (2007)142 Europe Pharm. Fund Multicentre | CHD and risk equivalent | Rosuvastatin 40 | 238 | Rosuvastatin 40 | 230 | 6 | 160190 | 5/4 0.78 (0.17, 3.53) | unclear | 1 | No
Patel (2006)143 Europe Pharm. Fund Multicentre | Participants with CAD not on recent lipid lowering drug treatment | Simvastatin 20 | 77 | Simvastatin 20 | 75 | 6 | 160 | 2/1 1.21 (0.32, 4.57) | unclear | 3 | No
Goldberg (2006)144 VYTAL North America Pharm. Fund Multicentre | T2DM, hemoglobin A- 1c < 8.5% and LDL-c > 100 mg/dL | Simvastatin 20–40 | 494 | Atorvastatin 10–40 | 732 | 6 | 145 | 3/10 0.44 (0.12, 1.61) | Adequate | 3 | No
Catapano (2006)193 North America Pharm. Fund Multicentre | Hypercholesterolemia, heterogeneous 10- year CHD risk estimates | RosuvastatinSimvastatin 20–80 | 1427 | Rosuvastatin 10–40 | 1428 | 6 | 173 | 16/17 0.94 (0.47, 1.87) | Adequate | 4 | No
Shankar (2007)168 Asia Pharm. Fund Multicentre | South Asians, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 114 | Simvastatin 10 | 116 | 12 | 127 | 0/0 | unclear | 2 | Yes
Reckless (2008)149 INFORCE International Pharm. Fund Multicentre | CHD patients on previous stable statin dose | Simvastatin 40 | 213 | Mixed statins | 211 | 12 | 92.5 | 44/42 1.05 (0.65, 1.68) | Adequate | 2 | No
Roeters van Lennep (2008)151 EASEGO Europe Pharm. Fund Multicentre | CHD and/or controlled type II DM patients not on target LDL-c despite prior low dose simvastatin or atorvastatin therapy | Simvastatin 20 | 178 | Simvastatin 40 or atorvastatin 20 | 189 | 12 | 115 | 9/7 1.38 (0.50, 3.80) | Unclear | 3 | No
Gouni-Berthold (2008)110 Europe Pharm. Fund Single | Healthy males with LDL-c < 190 mg/dL and < 60 years of age, previously not on lipid lowering treatment | Simvastatin 40 | 24 | Simvastatin 40 | 24 | 2 | 114.5 | 0/0 | Unclear | 2 | Yes
Conrad (2008)158 International Pharm. Fund Multicenter | Moderately high risk participants on atorvastatin 20 mg/day or statin naive and with LDL-c 100 mg/dL to <= 160 mg/dL | Atorvastatin 20 | 96 | Atorvastatin 40 | 98 | 6 | 119 | 0/0 | Adequate | 5 | No
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | 3/0 3.80 (0.19, 75.78) | Adequate | 5 | Yes
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10-year CHD risk > 20% | Atorvastatin 40 | 286 | Atorvastatin 80 | 289 | 6 | 89 | 9/5 1.85 (0.61, 5.58) | Adequate | 5 | No
Serious Adverse Events: all statins, lower versus higher doses, all clinical populations
Gaudiani (2005)121 North America Pharm. Fund Multicentre | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 104 | Simvastatin 40 | 110 | 24 | 93 | 5/1 5.51 (0.63, 47.94) | unclear | 3 | No
Feldman (2004)47 North America Pharm. Fund Multicentre | Participants with CHD or risk equivalent | Simvastatin 10–20 | 360 | Simvastatin 40 | 253 | 23 | 169 | 23/12 1.26 (0.63, 2.53) | unclear | 2 | No
Conrad (2008)158 International Pharm. Fund Multicenter | Moderately high risk participants on atorvastatin 20 mg/day or statin naive and with LDL-c 100 mg/dL to <= 160 mg/dL | Atorvastatin 20 | 96 | Atorvastatin 40 | 98 | 6 | 119 | 0/0 | Adequate | 5 | No
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | 3/0 3.80 (0.19, 75.78) | Adequate | 5 | Yes
Cancer, all trials
Goldberg (2004)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 539 | Simvastatin 20–80 | 229 | 48 | 175 | 6/1 2.57 (0.31, 21.44) | Adequate | 5 | No
Landray (2006)166 UK-HARP-II Europe Pharm. Fund Multicentre | Participants with renal disease and without definitive indication for cholesterol lowering | Simvastatin 20 | 102 | Simvastatin 20 | 101 | 24 | 119 | 4/0 9.27 (0.49, 174.53) | Adequate | 2 | Yes

Table F-2

Surrogate outcome – Achieving ATP-III target LDL-c using ezetimibe plus statin therapy compared with statin monotherapy

ATP III target for LDL-c
Trial | Population | Combination Statin Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Trial Baseline LDL-c (mg/dL) | Combo/mono Number of participants with events Odds ratio (95% CI) | AAC | Jadad Score | ITTA
Relative probability of attaining ATPIII LDL-c goal: all statins, all doses, all clinical populations
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 10–40 | 451 | Simvastatin 40 | 248 | 23 | 169 | 363/147 2.83 (2.01, 4.00) | unclear | 2 | no
Stein (2004)156 International Pharm. fund | 1° HC , LDL >= 130 mg/dL despite diet and atorvastatin 10 mg/day | Atorvastatin 40 | 278 | Atorvastatin 80 | 290 | 14 | 186 | 67/22 3.87 (2.31, 6.47) | unclear | 3 | yes
Ballantyne (2003)126 Ezetimibe Study Group International Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Atorvastatin 10–80 | 252 | Atorvastatin 10–80 | 245 | 12 | 183 | 215/180 2.10 (1.34, 3.29) | unclear | 2 | no
Stein (2008)148 International Pharm. fund | HC, Participants with documented statin associated muscle related side effects | Fluvastatin 80 | 64 | Fluvastatin 80 | 69 | 12 | 174 | 54/41 3.69 (1.61, 8.44) | Adequate | 5 | yes
Kerzner (2003)129 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Lovastatin 10–40 | 192 | Lovastatin 10–40 | 220 | 12 | 179 | 127/107 2.06 (1.38, 3.08) | unclear | 3 | yes
Melani (2003)127 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Pravastatin 10–40 | 204 | Pravastatin 10–40 | 203 | 12 | 178 | 144/97 2.62 (1.74, 3.94) | Adequate | 4 | yes
Davidson (2002)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 268 | Simvastatin 10–80 | 261 | 12 | 179 | 207/167 1.91 (1.30, 2.80) | Adequate | 4 | no
Shankar (2007)168 Asia Pharm. Fund Multicenter | South Asians, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 114 | Simvastatin 10 | 116 | 12 | 127 | 101/78 3.79 (1.89, 7.59) | unclear | 2 | yes
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 217 | Atorvastatin 20 | 210 | 6 | 124 | 169/109 3.26 (2.14, 4.96) | unclear | 3 | no
Cruz-Fernandez (2005)115 International Pharm. Fund Multicenter | Participants with CAD on low dose atorvastatins | Atorvastatin 10–20 | 219 | Atorvastatin 10–20 | 225 | 6 | 122 | 178/49 15.59 (9.80, 24.81) | unclear | 4 | no
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants not on ATP III target LDL-c (ATPIII criteria) | Simvastatin 10–80 | 923 | Atorvastatin 10–80 | 927 | 6 | 178 | 828/752 2.03(1.55, 2.65) | Adequate | 2 | no
Blagden (2007)140 Europe Pharm. Fund Multicenter | Participants with CAD, statin naïve | Atorvastatin 10 | 72 | Atorvastatin 10 | 76 | 6 | 157 | 66/36 12.22 (4.73, 31.58) | unclear | 4 | yes
Goldberg (2006_1)144 VYTAL North America Pharm. Fund Multicenter | T2DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dL | Simvastatin 20 | 238 | Atorvastatin 20 | 240 | 6 | 145 | 215/197 2.04 (1.19, 3.51) | Adequate | 3 | no
Goldberg (2006_2)144 VYTAL North America Pharm. Fund Multicenter | T2DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dL | Simvastatin 40 | 242 | Atorvastatin 40 | 241 | 6 | 145 | 226/214 1.78 (0.93, 3.40) | Adequate | 3 | no
Constance (2007)194 International Pharm. fund | Participants with T2DM on low dose atorvastatin | Simvastatin 20–40 | 442 | Atorvastatin 20 | 219 | 6 | 94 | 392/154 3.31 (2.19, 5.00 ) | Adequate | 3 | no
Pearson (2005)117 EASE North America Pharm. Fund Multicenter | Participants not meeting ATP III target LDL-c despite statin therapy | Mixed | 1940 | Mixed | 968 | 6 | 129 | 1377/199 9.45 (7.86, 11.36) | Adequate | 4 | no
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 235 | Rosuvastatin 40 | 230 | 6 | 190 | 221/182 4.16 (2.22, 7.79) | unclear | 1 | no
Catapano (2006)193 North America Pharm. Fund Multicenter | Hypercholesterolemia , heterogeneous 10-year CHD risk estimates | Simvastatin 20–80 | 1427 | Rosuvastatin 10–40 | 1428 | 6 | 173 | 1368/1328 1.75 (1.25, 2.43) | Adequate | 3 | no
Farnier (2005)114 International Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 179 | Simvastatin 10–20 | 186 | 6 | 123 | 133/31 14.46 (8.67, 24.10) | unclear | 5 | no
Brohet (2005)116 Europe Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 204 | Simvastatin 10–20 | 207 | 6 | 123 | 164/36 19.48 (11.83, 32.06) | unclear | 5 | no
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 37 | Simvastatin 40 | 33 | 6–24 | 93 | 28/13 4.79 (1.72, 13.35) | unclear | 3 | no
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals, DM subgroup | Simvastatin 10–80 | 73 | Simvastatin 10–80 | 80 | 23 | 136 | 61/14 23.96 (10.28, 55.84) | unclear | 3 | no
Reckless (2008)149 INFORCEInterbr>national Pharm. Fund Multicentre | CHD patients on previous stable statin dose | Simvastatin 40 | 197 | Double the previous (mixed) statin dose | 187 | 12 | 92.5 | 169/135 2.32 (1.39, 3.88) | Adequate | 2 | No
Roeters van Lennep (2008)151 EASEGO Europe Pharm. Fund Multicentre | CHD and/or controlled type II DM patients not on target LDL-c despite prior low dose simvastatin or atorvastatin therapy | Simvastatin 20 | 178 | Simvastatin 40 or atorvastatin 20 | 189 | 12 | 115 | 119/49 5.76 (3.67, 9.05) | Unclear | 3 | Yes
Relative probability of attaining ATPIII LDL-c goal: all statins, lower versus higher doses, all clinical populations
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 20 | 109 | Simvastatin 40 | 248 | 23 | 169 | 90/147 3.25 (1.87, 5.67) | unclear | 2 | no
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 37 | Simvastatin 40 | 33 | 6–24 | 93 | 28/13 4.79 (1.72, 13.35) | unclear | 3 | no
Roeters van Lennep (2008)151 EASEGO Europe Pharm. Fund Multicentre | CHD and/or controlled type II DM patients not on target LDL-c despite prior low dose simvastatin or atorvastatin therapy | Simvastatin 20 | 110 | Simvastatin 40 | 115 | 12 | 115 | 80/28 8.29 (4.56, 15.07) | Unclear | 3 | Yes
Relative probability of attaining ATPIII LDL-c goal: all statins, all doses, intensive lipid lowering populations and clinical subgroups
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 235 | Rosuvastatin 40 | 230 | 6 | 190 | 221/182 4.16 (2.22, 7.79) | unclear | 1 | no
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 217 | Atorvastatin 20 | 210 | 6 | 124 | 169/109 3.26 (2.14, 4.96) | unclear | 3 | no
Blagden (2007)140 Europe Pharm. Fund Multicenter | Participants with CAD, statin naïve | Atorvastatin 10 | 72 | Atorvastatin 10 | 76 | 6 | 157 | 66/36 12.22 (4.73, 31.58) | unclear | 4 | yes
Brohet (2005)116 Europe Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 204 | Simvastatin 10–20 | 207 | 6 | 123 | 164/36 19.48 (11.83, 32.06) | unclear | 5 | no
Pearson (2005)117 EASE North America Pharm. Fund Multicenter | Participants not meeting ATP III target LDL-c despite statin therapy | Mixed | 768 | Mixed | 395 | 6 | 129 | 546/83 9.25 (6.93, 12.33) | Adequate | 4 | no
Constance (2007)194 International Pharm. fund | Participants with T2DM on low dose atorvastatin | Simvastatin 20–40 | 442 | Atorvastatin 20 | 219 | 6 | 94 | 392/154 3.31 (2.19, 5.00 ) | Adequate | 3 | no
Cruz-Fernandez(2005)115 International Pharm. Fund Multicenter | all with vascular disease LDL-c>190 and/or DM | Atorvastatin 10–20 | 219 | Atorvastatin 10–20 | 225 | 6 | 122 | 178/49 15.59 (9.80, 24.81) | unclear | 4 | no
Farnier (2005)114 International Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 179 | Simvastatin 10–20 | 186 | 6 | 123 | 133/31 14.46 (8.67, 24.10) | unclear | 5 | no
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent Participants with | Simvastatin 10–40 | 451 | Simvastatin 40 | 248 | 23 | 169 | 363/147 2.83 (2.01, 4.00) | unclear | 2 | no
Gaudiani (2005)121 North America Pharm. Fund Multicenter | T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 37 | Simvastatin 40 | 33 | 6–24 | 93 | 28/13 4.79 (1.72, 13.35) | unclear | 3 | no
Goldberg (2006_1)144 VYTAL North America Pharm. Fund Multicenter | T2DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dL | Simvastatin 20 | 238 | Atorvastatin 20 | 240 | 6 | 145 | 215/197 2.04 (1.19, 3.51) | Adequate | 3 | no
Goldberg (2006_2)144 VYTAL North America Pharm. Fund Multicenter | T2DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dL | Simvastatin 40 | 242 | Atorvastatin 40 | 241 | 6 | 145 | 226/214 1.78 (0.93, 3.40) | Adequate | 3 | no
Stein (2008)148 International Pharm. fund | HC, Participants with documented statin associated muscle related side effects | Fluvastatin 80 | 30 | Fluvastatin 80 | 33 | 12 | 174 | 24/14 5.43(1.75, 16.80) | Adequate | 5 | yes
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals, DM subgroup | Simvastatin 10–80 | 73 | Simvastatin 10–80 | 80 | 23 | 136 | 61/14 23.96 (10.28, 55.84) | unclear | 3 | no
Shankar (2007)168 Asia Pharm. Fund Multicenter | South Asians, heterogeneous 10-year CHD risk estimates | Simvastatin 10 | 85 | Simvastatin 10 | 85 | 12 | 127 | 75/59 3.31 (1.48, 7.39) | unclear | 2 | yes
Catapno (2006)193 North America Pharm. Fund Multicenter | Participants with DM | Simvastatin 20–80 | 186 | Rosuvastatin 20–40 | 181 | 6 | 173 | 170/161 1.32 (0.66, 2.64) | Adequate | 3 | No
Reckless (2008)149 INFORCE International Pharm. Fund Multicentre | CHD patients on previous stable statin dose | Simvastatin 40 | 197 | Double the previous (mixed) statin dose | 187 | 12 | 92.5 | 169/135 2.32 (1.39, 3.88) | Adequate | 2 | No
Roeters van Lennep (2008)151 EASEGO Europe Pharm. Fund Multicentre | CHD and/or controlled type II DM patients not on target LDL-c despite prior low dose simvastatin or atorvastatin therapy | Simvastatin 20 | 178 | Simvastatin 40 or atorvastatin 20 | 189 | 12 | 115 | 119/49 5.76 (3.67, 9.05) | Unclear | 3 | Yes
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants with DM not at LDL-c ATP III goal off lipid lowering treatment | Simvastatin 10–80 | 212 | Atorvastatin 10–80 | 201 | 6 | 178 | 170/161 2.94 (1.70, 5.06) | Adequate | 2 | no
Reckless (2008)149 INFORCE International Pharm. Fund Multicentre | Participants with diabetes mellitus | Simvastatin 40 | 57 | Double the previous (mixed) statin dose | 51 | 12 | 92.5 | 49/39 1.88 (0.70, 5.06) | Adequate | 2 | No
Reckless (2008)149 INFORCE International Pharm. Fund Multicentre | Female participants only | Simvastatin 40 | 40 | Double the previous (mixed) statin dose | 36 | 12 | 92.5 | 31/21 2.46 (0.91, 6.65) | Adequate | 2 | No
Farnier (2005)114 International Pharm. Fund Multicentre | Female participants only | Simvastatin 10–20 | 56 | Simvastatin 10–20 | 57 | 6 | 123 | 43/9 17.64 (6.86, 45.36) | Unclear | 5 | No
Pearson (2005)117 EASE North America Pharm. Fund Multicenter | Participants of African descent not meeting ATP III target LDL-c despite statin therapy | Mixed | 135 | Mixed | 73 | 6 | 129 | 85/24 3.47 (1.90, 6.33) | Adequate | 4 | no
Pearson (2005) 117 EASE North America Pharm. Fund Multicenter | Hispanic participants not meeting ATP III target LDL-c despite statin therapy | Mixed | 71 | Mixed | 42 | 6 | 129 | 46/8 7.82 (3.14, 19.45) | Adequate | 4 | no
Relative probability of attaining ATPIII LDL-c goal: all statins, lower versus higher doses, intensive lipid lowering populations and clinical subgroups
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 20 | 109 | Simvastatin 40 | 248 | 23 | 169 | 90/147 3.25 (1.87, 5.67) | unclear | 2 | no
Gaudiani (2005) 121 North America Pharm. Fund Multicenter | T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 37 | Simvastatin 40 | 33 | 6–24 | 93 | 28/13 4.79 (1.72, 13.35) | unclear | 3 | no
Roeters van Lennep (2008)151 EASEGO Europe Pharm. Fund Multicentre | CHD and/or controlled type II DM patients not on target LDL-c despite prior low dose simvastatin or atorvastatin therapy | Simvastatin 20 | 110 | Simvastatin 40 | 115 | 12 | 115 | 80/28 8.29 (4.56, 15.07) | Unclear | 3 | Yes

Table F-3

Surrogate outcome – LDL-c using ezetimibe plus statin therapy compared with statin monotherapy

Low density lipoprotein cholesterol
Trial | Population | Combination Statin Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Mean Baseline LDL-c (mg/dL) | Combo- mono: mean difference (95% CI) mg/dL | AAC | Jadad Score | ITTA
Combination – monotherapy, difference in mean percentage change from baseline (%): all statins, all doses, all clinical populations
Kastelein (2008)42 ENHANCE International Pharm. fund | FHC, LDL-c > 210 mg/dL | Simvastatin 80 | 357 | Simvastatin 80 | 363 | 96 | 318 | −16.50 (−16.63, −16.37) | Adequate | 3 | no
Ballantyne (2003)126 Ezetimibe Study Group International Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Atorvastatin 80 | 201 | Atorvastatin 80 | 45 | 52 | 183 | −10.00 (−15.76, −4.24) | unclear | 2 | no
Ballantyne (2004_b)46 North America Pharm. Fund Multicenter | HC, heterogeneous 10-year CHD risk estimates | Simvastatin 80 | 432 | Atorvastatin 80 | 223 | 24 | 180 | −6.90 (−9.27, −4.53) | unclear | 3 | no
Landray (2006)166 UK-HARP-II Europe Pharm. Fund Multicenter | Participants with renal disease and without definitive indication for cholesterol lowering | Simvastatin 20 | 102 | simvastatin 20 | 101 | 24 | 119 | −21.00 (−30.74, −11.26) | Adequate | 2 | no
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 6–24 | 93 | −20.50 (−26.60, −14.40) | unclear | 3 | no
Bays (2004)154 North America Pharm. Fund Multicenter | 1 ° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 539 | Simvastatin 10–80 | 559 | 6–26 | 178 | −14.90 (−16.46, −13.34) | Adequate | 5 | no
Berthold (2006)109 Europe Pharm. Fund Single centre | Healthy male participants. Low risk | Simvastatin 40 | 24 | Simvastatin 40 | 24 | 2–3 | 114 | −18.90 (−24.97, −12.83) | unclear | 2 | yes
Stein (2004)156 International Pharm. fund | LDL >= 130 mg/dL despite diet and atorvastatin 10 mg/day | Atorvastatin 40 | 278 | Atorvastatin 80 | 290 | 14 | 186 | −13.60 (−16.10, −11.10) | unclear | 3 | yes
Rodney (2006)111 Pharm. Fund Multicenter | African descent, 1° HC | Simvastatin 20 | 124 | Simvastatin 20 | 123 | 12 | 176 | −17.20 (−21.13, −13.27) | Adequate | 5 | no
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals | Simvastatin 80 | 344 | Simvastatin 80 | 78 | 12 | 136 | −27.00 (−34.80, −19.20) | unclear | 3 | no
Goldberg (2004)48 Ezetimibe Study Group International Pharm. fund | statin naïve, 1 ° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 323 | Simvastatin 10–80 | 322 | 12 | 175 | −14.70 (−17.13, −12.27) | Adequate | 5 | no
Melani (2003)127 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Pravastatin 10–40 | 204 | Pravastatin 10–40 | 205 | 12 | 178 | −13.40 (−15.89, −10.91) | Adequate | 4 | yes
Kerzner (2003)129 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Lovastatin 10–40 | 181 | Lovastatin 10–40 | 202 | 12 | 179 | −15.00 (−17.78, −12.22) | unclear | 3 | yes
Davidson (2002)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 253 | Simvastatin 10–80 | 249 | 12 | 179 | −15.20 (−17.70, −12.70) | Adequate | 4 | no
Gagne (2002_1)132 Ezetimibe Study Group International Pharm. fund | Homozygous FHC, 7 (14%) participants between 12–18 years of age | Atorvastatin 80 | 12 | Atorvastatin 80 | 12 | 12 | 309 | −21.16 (−30.97, −11.35) | unclear | 3 | no
Gagne (2002_2)132 Ezetimibe Study Group International Pharm. fund | Homozygous FHC, 7 (14%) participants between 12–18 years of age | Simvastatin 80 | 5 | Simvastatin 80 | 5 | 12 | 309 | −18.83 (−36.43, −1.23) | unclear | 3 | no
McKenney (2007_1)139 COMPELL study North America Pharm. Fund Multicenter | HC, heterogeneous 10-year CHD risk estimates | Simvastatin 40 | 72 | Rosuvastatin40 | 73 | 12 | 197 | −4.00 (−8.95, 0.95) | unclear | 2 | no
Shankar (2007)168 Asia Pharm. Fund Multicenter | South Asians, heterogeneous 10-year CHD risk estimates | Simvastatin 10 | 114 | Simvastatin 10 | 116 | 12 | 127 | −7.40 (−16.33, 1.53) | unclear | 2 | yes
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals, subgroup with DM | Mixed 10–80 | 88 | Mixed 10–80 | 94 | 8 | 136 | −26.10 (−30.69, −21.51) | unclear | 3 | no
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 215 | Atorvastatin 20 | 207 | 6 | 124 | −12.50 (−15.83, −9.17) | unclear | 35 | no
Farnier (2005)114 International Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 102 | Simvastatin 10–20 | 101 | 6 | 123 | −24.30 (−27.78, −20.82) | unclear | 5 | no
Cruz-Fernandez (2005)115 International Pharm. Fund Multicenter | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 219 | Atorvastatin 10–20 | 224 | 6 | 122 | −26.90 (−29.80, − 24.00) | unclear | 4 | no
Brohet (2005)116 Europe Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 204 | Simvastatin 10–20 | 207 | 6 | 123 | −23.00 (−25.86, − 20.14) | unclear | 5 | no
Pearson (2005)117 EASE North America Pharm. Fund Multicenter | Participants not meeting ATP III target LDL-c despite statin therapy | Mixed | 1940 | Mixed | 968 | 6 | 129 | −23.10 (−24.45, −21.75) | Adequate | 4 | no
Pearson (2005)117 EASE North America Pharm. Fund Multicenter | Participants not meeting ATP III target LDL-c despite statin therapy, African descent subgroup | Simvastatin 20 | 174 | Simvastatin 20 | 93 | 6 | 129 | −23.00 (−27.55, − 18.45) | Adequate | 4 | no
Pearson (2005)117 EASE North America Pharm. Fund Multicenter | Participants not meeting ATP III target LDL-c despite statin therapy, Hispanic subgroup | Mixed | 94 | Mixed | 53 | 6 | 129 | −21.10 (−27.16, −15.04) | Adequate | 4 | no
Ballantyne (2005_1)118 VYVA North America Pharm. Fund Multicenter | Participants not on ATP III target LDL-c | Simvastatin 20 | 233 | Atorvastatin 20 | 230 | 6 | 178 | −6.90 (−9.49, −4.31) | Adequate | 2 | no
Ballantyne (2005_2)118 VYVA North America Pharm. Fund Multicenter | Participants not on ATP III target LDL-c | Simvastatin 40 | 236 | Atorvastatin 40 | 232 | 6 | 178 | −9.10 (−11.69, −6.51) | Adequate | 2 | no
Ballantyne (2005_3)118 VYVA North America Pharm. Fund Multicenter | Participants not on ATP III target LDL-c | Simvastatin 80 | 224 | Atorvastatin 80 | 230 | 6 | 178 | −5.70 (−8.39, −3.01) | Adequate | 2 | no
Blagden (2007)140 Europe Pharm. Fund Multicenter | Participants with CAD, statin naïve | Atorvastatin 10 | 72 | Atorvastatin 10 | 76 | 6 | 157 | −14.10 (−17.92, −10.28) | unclear | 4 | yes
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 235 | Rosuvastatin 40 | 230 | 6 | 190 | −24.60 (−29.39, −19.81) | unclear | 1 | no
Patel (2006)143 Europe Pharm. Fund Multicenter | Participants with CAD not on recent lipid lowering drug treatment | Simvastatin 20 | 72 | Simvastatin 20 | 71 | 6 | 160 | −14.60 (−19.06, −10.14) | unclear | 3 | no
Goldberg (2006_1)144 VYTAL North America Pharm. Fund Multicenter | T2DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dL | Simvastatin 20 | 238 | Atorvastatin 20 | 240 | 6 | 145 | −9.00 (-11.55, -6.45) | Adequate | 3
Goldberg (2006_2)144 VYTAL North America Pharm. Fund Multicenter | T2DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dL | Simvastatin 40 | 242 | Atorvastatin 40 | 241 | 6 | 145 | −6.70 (−9.25, −4.15) | Adequate | 3 | no
Catapano (2006)193 North America Pharm. Fund Multicenter | Hypercholesterole mia, heterogeneous 10- year CHD risk estimates | Simvastatin 20–80 | 1427 | Rosuvastatin 10–40 | 1428 | 6 | 173 | −4.20 (−5.03, −3.37) | Adequate | 3 | no
Constance (2007)194 International Pharm. fund | Participants with T2DM on low dose atorvastatin | Simvastatin 20 | 210 | Atorvastatin 20 | 213 | 6 | 94 | −17.66 (−22.78, −12.54) | Adequate | 3 | no
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 40 | 97 | Simvastatin 40 | 248 | 23 | 169 | −14.00 (−17.53, −10.47) | unclear | 2 | no
Kosoglou (2004)124 Europe Pharm. Fund Single centre | Healthy participants with LDL-c >= 130 mg/dL and BMI < 31kg/m2. Low risk | Rosuvastatin 10 | 12 | Rosuvastatin 10 | 11 | 2 | 158 | −15.90 (−22.16, −9.64) | unclear | 2 | yes
Gouni-Berthold (2008)110 Europe Pharm. Fund Single | Healthy males with LDL-c < 190 mg/dL and < 60 years of age, previously not on lipid lowering treatment | Simvastatin 40 | 24 | Simvastatin 40 | 24 | 2 | 114.5 | −18.90 (−24.97, − 12.83) | Unclear | 2 | Yes
Conrad (2008)158 International Pharm. Fund Multicenter | Moderately high risk participants on atorvastatin 20 mg/day or statin naive and with LDL-c 100 mg/dL to <= 160 mg/dL | Atorvastatin 20 | 92 | Atorvastatin 40 | 92 | 6 | 119 | −19.90 (−25.17, −14.63) | Adequate | 5 | No
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | −13.36 (−18.31, −8.41) | Adequate | 5 | Yes
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10-year CHD risk > 20% | Atorvastatin 40 | 277 | Atorvastatin 80 | 279 | 6 | 89 | −16.40 (−19.45, −13.35) | Adequate | 5 | No
Combination – monotherapy, difference in mean percentage change from baseline (%):all statins, lower versus higher doses, all clinical populations
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 6–24 | 93 | −20.50 (−26.60, − 14.40) | unclear | 3 | no
Bays (2004_1)154 North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 222 | Simvastatin 40 | 108 | 6–26 | 178 | −5.90 (−8.80, −3.00) | Adequate | 5 | no
Bays (2004_2)154 North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 106 | Simvastatin 80 | 224 | 6–26 | 178 | −3.00 (−5.93, −0.07) | Adequate | 5 | no
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 20 | 109 | Simvastatin 40 | 248 | 23 | 169 | −10.00 (−13.19, −6.81) | unclear | 2 | no
Goldberg (2004_1)48 Ezetimibe Study Group International Pharm. fund | statin naïve, 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10 | 87 | Simvastatin 40 | 90 | 12 | 175 | −4.70 (−8.19, −−0.49) | Adequate | 5 | no
Goldberg (2004_2)48 Ezetimibe Study Group International Pharm. fund | statin naïve, 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 86 | Simvastatin 80 | 87 | 12 | 175 | −4.90 (−9.21, −0.59) | Adequate | 5 | no
Davidson (2002_1)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10 | 67 | Simvastatin 40 | 64 | 12 | 179 | −8.12 (−13.03, −3.21) | Adequate | 4 | no
Davidson (2002_2)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 68 | Simvastatin 80 | 66 | 12 | 179 | −0.53 (−5.39, −4.33) | Adequate | 4 | no
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | −13.36 (−18.31, −8.41) | Adequate | 5 | Yes
Combination – monotherapy, difference in mean percentage change from baseline (%):all statins, all doses, intensive lipid lowering populations and clinical subgroups
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 215 | Atorvastatin 20 | 207 | 6 | 124 | −12.50 (−15.83, −9.17) | unclear | 3 | no
Farnier (2005)114 International Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 102 | Simvastatin 10–20 | 101 | 6 | 123 | −24.30 (−27.78, − 20.82) | unclear | 5 | no
Cruz-Fernandez (2005)115 International Pharm. Fund Multicenter | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 219 | Atorvastatin 10–20 | 224 | 6 | 122 | −26.90 (−29.80, − 24.00) | unclear | 4 | no
Brohet (2005)116 Europe Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 204 | Simvastatin 10–20 | 207 | 6 | 123 | −23.00 (−25.86, − 20.14) | unclear | 5 | no
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals, subgroup with DM | Mixed 10–80 | 88 | Mixed 10–80 | 94 | 8 | 136 | −26.10 (−30.69, − 21.51) | unclear | 3 | no
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 6–24 | 93 | −20.50 (−26.60, − 14.40) | unclear | 3 | no
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 40 | 186 | Simvastatin 40 | 181 | 23 | 169 | −14.00 (−17.53, −10.47) | unclear | 2 | no
Gagne (2002_2)132 Ezetimibe Study Group International Pharm. fund | Homozygous FHC, 7 (14%) participants between 12–18 years of age | Simvastatin 80 | 5 | Simvastatin 80 | 5 | 12 | 309 | −18.83 (−36.43, −1.23) | unclear | 3 | no
Blagden (2007)140 Europe Pharm. Fund Multicenter | Participants with CAD, statin naïve | Atorvastatin 10 | 72 | Atorvastatin 10 | 76 | 6 | 157 | −14.10 (−17.92, − 10.28) | unclear | 4 | yes
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 235 | Rosuvastatin 40 | 230 | 6 | 190 | −24.60 (−29.39, − 19.81) | unclear | 1 | no
Patel (2006)143 Europe Pharm. Fund Multicenter | Participants with CAD not on recent lipid lowering drug treatment | Simvastatin 20 | 72 | Simvastatin 20 | 71 | 6 | 160 | −14.60 (−19.06, − 10.14) | unclear | 3 | no
Goldberg (2006_2)144 VYTAL North America Pharm. Fund Multicenter | T2DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dL | Simvastatin 40 | 242 | Atorvastatin 40 | 241 | 6 | 145 | −6.70 (−9.25, −4.15) | Adequate | 3 | no
Constance (2007)194 International Pharm. fund | Participants with T2DM on low dose atorvastatin | Simvastatin 20 | 210 | Atorvastatin 20 | 213 | 6 | 94 | −17.66 (−22.78, − 12.54) | Adequate | 3 | no
Kastelein (2008)42 ENHANCE International Pharm. fund | FHC, LDL-c > 210 mg/dL | Simvastatin 80 | 357 | Simvastatin 80 | 363 | 96 | 318 | −16.50 (−16.63, − 16.37) | Adequate | 3 | no
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants with DM not at LDL-c ATP III goal off lipid lowering treatment | Simvastatin 10–80 | 212 | Atorvastatin 10–80 | 201 | 6 | 178 | −10.20 (−13.25, −7.15) | Adequate | 2 | no
Bays (2004)154 North America Pharm. Fund Multicentre | Mixed 10 years CHD risk participants who were protocol compliant in a previous base study | Simvastatin 10–80 | 86 | Simvastatin 10–80 | 69 | 6–26 | 178 | −9.40 (−13.62, − 5.18) | Adequate | 5 | No
Catapno (2006)193 North America Pharm. Fund Multicenter | Participants with DM | Simvastatin 20–80 | 186 | Rosuvastatin 10–40 | 181 | 6 | 173 | −4.30 (−6.79, − 1.81) | Adequate | 3 | No
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10-year CHD risk > 20% | Atorvastatin 40 | 277 | Atorvastatin 80 | 279 | 6 | 89 | −16.40 (−19.45, −13.35) | Adequate | 5 | No
Bays (2004)154 North America Pharm. Fund Multicentre | Participants with DM | Simvastatin 10–80 | 34 | Simvastatin 10–80 | 37 | 6–26 | 178 | −14.40 (−21.18, −7.62) | Adequate | 5 | No
Rodney (2006)111 Pharm. Fund Multicentre | African descent, 1° HC | Simvastatin 20 | 124 | Simvastatin 20 | 124 | 12 | 176 | −17.2 (−21.1, − 13.27) | Adequate | 5 | No
Farnier (2005)114 International Pharm. Fund Multicentre | Participants with CAD on low dose simvastatin -- African descent | Simvastatin 10–20 | 1 | Simvastatin 10–20 | 1 | 6 | 111 | NA | unclear | 5 | No
Pearson (2005)117 EASE North America Pharm. Fund Multicentre | Participants not meeting ATP III target LDL-c despite statin therapy -- African descent | Mixed | 174 | Mixed | 93 | 6 | 129 | −23 (−27.5, − 18.45) | Adequate | 4 | No
Bays (2004)154 North America Pharm. Fund Multicentre | Participants with CHD | Simvastatin 10–80 | 34 | Simvastatin 10–80 | 37 | 6–26 | 180 | −9.40 (−13.62, − 5.18) | Adequate | 5 | No
Farnier (2005)114 International Pharm. Fund Multicentre | Participants with CAD on low dose simvastatin – Females only | Simvastatin 10–20 | 56 | Simvastatin 10–20 | 57 | 6 | 111 | −23.99 (−30.53, −17.45) | unclear | 5 | No
Davidson (2002)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates -- Females only | Simvastatin 10–80 | 152 | Simvastatin 10–80 | 147 | 12 | 179 | 13.4 (9.87, 16.93) | Adequate | 4 | no
Dobs (2003)169 Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates, with (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day -- Females only, | Simvastatin 20 | 29 | Simvastatin 40 | 15 | 4 | 169 | −14.46 (−21.90, −7.02) | Adequate | 5 | Yes
Pearson (2005)117 EASE North America Pharm. Fund Multicenter | Participants not meeting ATP III target LDL-c despite statin therapy, Hispanic subgroup | Mixed | 94 | Mixed | 53 | 6 | 129 | −21.10 (−27.16, − 15.04) | Adequate | 4 | no
Gagne (2002_1)132 Ezetimibe Study Group International Pharm. fund | Homozygous FHC, 7 (14%) participants between 12–18 years of age – LDL > 190 | Atorvastatin 80 | 12 | Atorvastatin 80 | 12 | 12 | 309 | −21.16 (−30.97, − 11.35) | unclear | 3 | no
Gagne (2002_2)132 Ezetimibe Study Group International Pharm. fund | Homozygous FHC, 7 (14%) participants between 12–18 years of age, LDL > 190 | Simvastatin 80 | 5 | Simvastatin 80 | 5 | 12 | 309 | −18.83 (−36.43, −1.23) | unclear | 3 | no
Kastelein (2008)42 ENHANCE International Pharm. fund | FHC, LDL-c > 210 mg/dL | Simvastatin 80 | 357 | Simvastatin 80 | 363 | 96 | 318 | −16.50 (−16.63, − 16.37) | Adequate | 3 | no
Combination – monotherapy, difference in mean percentage change from baseline (%):all statins, lower versus higher doses, intensive lipid lowering populations and clinical subgroups
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 6–24 | 93 | −20.50 (−26.60, − 14.40) | unclear | 3 | no
Bays (2004_1)154 North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 222 | Simvastatin 40 | 108 | 6–26 | 178 | −5.90 (−8.80, −3.00) | Adequate | 5 | no
Bays (2004_2)154 North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 106 | Simvastatin 80 | 224 | 6–26 | 178 | −3.00 (−5.93, −0.07) | Adequate | 5 | no
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 20 | 109 | Simvastatin 40 | 248 | 23 | 169 | −10.00 (−13.19, −6.81) | unclear | 2 | no
Goldberg (2004_1)48 Ezetimibe Study Group International Pharm. fund | statin naïve, 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 87 | Simvastatin 40 | 90 | 12 | 175 | −4.70 (−8.19, −-0.49) | Adequate | 5 | no
Goldberg (2004_2)48 Ezetimibe Study Group International Pharm. fund | statin naïve, 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 86 | Simvastatin 80 | 87 | 12 | 175 | −4.90 (−9.21, −0.59) | Adequate | 5 | no
Davidson (2002_1)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 67 | Simvastatin 40 | 64 | 12 | 179 | −8.12 (−13.03, −3.21) | Adequate | 4 | no
Davidson (2002_2)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 68 | Simvastatin 80 | 66 | 12 | 179 | −0.53 (−5.39, −4.33) | Adequate | 4 | no
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | −13.36 (−18.31, −8.41) | Adequate | 5 | Yes
Davidson (2002_1)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates -- Females only | Simvastatin 10 | 36 | Simvastatin 40 | 35 | 12 | 179 | −9.80 (−16.05, − 3.55) | Adequate | 4 | no
Davidson (2002_2)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates -- Females only | Simvastatin 20 | 34 | Simvastatin 80 | 37 | 12 | 179 | −1.8 (9.70, 6.10) | Adequate | 4 | no
Dobs (2003)169 Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates, with (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day -- Females only, | Simvastatin 20 | 29 | Simvastatin 40 | 15 | 4 | 169 | −14.46 (−21.90, −7.02) | Adequate | 5 | Yes

Table F-4

Surrogate outcome – HDL-c using ezetimibe plus statin therapy compared with statin monotherapy

High density lipoprotein - cholesterol
Trial | Population | Combination Statin Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Mean Baseline LDL-c (mg/dL) | Combo-mono: mean difference (95% CI) | AAC | Jadad Score | ITTA
Combination – monotherapy, difference in mean percentage change from baseline (%):all statins, all doses, all clinical populations
Kastelein (2008)42 ENHANCE International Pharm. fund | FHC, LDL-c > 210 mg/dL | Simvastatin 80 | 357 | Simvastatin 80 | 363 | 96 | 318 | 2.40 (−0.23, 5.03) | Adequate | 3 | No
Ballantyne (2003)126 Ezetimibe Study Group International Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Atorvastatin 80 | 201 | Atorvastatin 80 | 45 | 52 | 183 | 0.90 (−3.04, 4.84) | unclear | 2 | No
Ballantyne (2004_b)46 North America Pharm. Fund Multicenter | HC, heterogeneous 10-year CHD risk estimates | Simvastatin 80 | 432 | Atorvastatin 80 | 223 | 24 | 180 | 5.80 (3.43, 8.17) | unclear | 3 | No
Stein (2004)156 International Pharm. Fund | 1° HC , LDL >= 130 mg/dL despite diet and atorvastatin 10 mg/day | Rosuvastatin 40 | 278 | Atorvastatin 80 | 290 | 14 | 186 | 2.70 (0.76, 4.64) | unclear | 3 | Yes
Davidson (2002)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 253 | Simvastatin 10–80 | 249 | 12 | 179 | 2.40 (0.18, 4.62) | Adequate | 4 | No
Goldberg (2004)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 323 | Simvastatin 10–80 | 322 | 12 | 175 | 0.60 (−1.33, 2.53) | Adequate | 5 | No
Kerzner (2003)129 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Lovastatin 10–40 | 181 | Lovastatin 10–40 | 202 | 12 | 179 | 5.00 (2.22, 7.78) | unclear | 3 | Yes
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals | Simvastatin 80 | 344 | Simvastatin 80 | 78 | 12 | 136 | 2.60 (−2.17, 7.37) | unclear | 3 | No
McKenney (2007_1)139 COMPELL study North America Pharm. Fund Multicenter | HC, heterogeneous 10-year CHD risk estimates | Simvastatin 40 | 72 | Rosuvastatin 40 | 73 | 12 | 197 | 3.00 (−1.95, 7.95) | unclear | 2 | No
Melani (2003)127 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Pravastatin 10–40 | 204 | Pravastatin 10–40 | 205 | 12 | 178 | 1.40 (−0.82, 3.62) | Adequate | 4 | Yes
Shankar (2007)168 Asia Pharm. Fund Multicenter | South Asians, heterogeneous 10-year CHD risk estimates | Simvastatin 10 | 114 | Simvastatin 10 | 116 | 12 | 127 | 2.70 (−2.56, 7.96) | unclear | 2 | Yes
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 235 | Rosuvastatin 40 | 230 | 6 | 190 | 2.32 (−0.83, 5.47) | unclear | 1 | No
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 215 | Atorvastatin 20 | 207 | 6 | 124 | 2.20 (−0.02, 4.42) | unclear | 3 | No
Blagden (2007)140 COMPELL study North America Pharm. Fund Multicenter | Participants with CAD, statin naïve | Atorvastatin 10 | 72 | Atorvastatin 10 | 76 | 6 | 197 | −0.30 (−4.22, 3.62) | unclear | 4 | No
Brohet (2005)116 Europe Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 204 | Simvastatin 10–20 | 207 | 6 | 123 | −0.40 (−2.91, 2.11) | unclear | 5 | No
Catapano (2006)193 North America Pharm. Fund Multicenter | Hypercholesterol emia, heterogeneous 10-year CHD risk estimates | Simvastatin 20–80 | 1427 | Rosuvastatin 10–40 | 1428 | 6 | 173 | 0.00 (−0.83, 0.83) | Adequate | 3 | No
Constance (2007)194 International Pharm. fund | Participants with T2DM on low dose atorvastatin | Simvastatin 20–40 | 439 | Atorvastatin 20 | 218 | 6 | 94 | 0.20 (−2.05, 2.45) | Adequate | 3 | No
Cruz- Fernandez (2005)115 International Pharm. Fund Multicenter | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 219 | Atorvastatin 10–20 | 225 | 6 | 122 | 2.80 (0.47, 5.13) | unclear | 4 | No
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinedione s, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 6–24 | 93 | −0.10 (−3.42, 3.22) | unclear | 3 | No
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 10–40 | 451 | Simvastatin 20 | 248 | 5 | 169 | 1.88 (0.06, 3.70) | unclear | 2 | No
Bays (2007)154 North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 539 | Simvastatin 10–80 | 559 | 6–26 | 178 | 0.80 (−0.72, 2.32) | Adequate | 5 | No
Berthold (2006)109 Europe Pharm. Fund Single centre | Healthy male participants. Low risk | Simvastatin 40 | 24 | Simvastatin 40 | 24 | 2–3 | 114 | −2.20 (−7.79, 3.39) | unclear | 2 | Yes
Kosoglou (2004)124 Europe Pharm. Fund Single centre | Healthy participants with LDL-c >= 130 mg/dL and BMI < 31kg/m2. Low risk | Rosuvastatin 10 | 12 | Rosuvastatin 10 | 11 | 2 | 158 | −2.80 (−11.57, 5.97) | unclear | 2 | Yes
Landray (2006)166 UK-HARP-II Europe Pharm. Fund Multicenter | Participants with renal disease and without definitive indication for cholesterol lowering | Simvastatin 20 | 102 | simvastatin 20 | 101 | 24 | 119 | 3.00 (−2.84, 8.84) | Adequate | 2 | Yes
Pearson (2005)117 EASE North America Pharm. Fund Multicenter | Participants not meeting ATP III target LDL-c despite statin therapy | Mixed | 1940 | Mixed | 968 | 6 | 129 | 2.10 (1.20, 3.00) | Adequate | 4 | No
Gouni-Berthold (2008)110 Europe Pharm. Fund Single | Healthy males with LDL-c < 190 mg/dL and < 60 years of age, previously not on lipid lowering treatment | Simvastatin 40 | 24 | Simvastatin 40 | 24 | 2 | 114.5 | −2.20 (−7.79, 3.39) | Unclear | 2 | Yes
Conrad (2008)158 International Pharm. Fund Multicenter | Moderately high risk participants on atorvastatin 20 mg/day or statin naive and with LDL-c 100 mg/dL to <= 160 mg/dL | Atorvastatin 20 | 92 | Atorvastatin 40 | 92 | 6 | 119 | 2.40 (1.97, 2.83) | Adequate | 5 | No
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10- year CHD risk > 20% | Atorvastatin 40 | 277 | Atorvastatin 80 | 279 | 6 | 89 | 0.50 (−1.16, 2.16) | Adequate | 5 | No
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants with DM not at LDL-c ATP III goal off lipid lowering treatment | Simvastatin 10–80 | 212 | Atorvastatin 10–80 | 201 | 6 | 178 | 2.60 (0.10, 5.10) | Adequate | 2 | no
Goldberg (2006_1)144 VYTAL North America Pharm. Fund Multicenter | Participants with type II DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dl | Simvastatin 20 | 240 | Atorvastatin 20 | 238 | 6 | 145 | 3.50 1.28, 5.72) | Adequate | 3 | No
Goldberg (2006_2)144 VYTAL North America Pharm. Fund Multicenter | Participants with type II DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dl | Simvastatin 40 | 241 | Atorvastatin 40 | 242 | 6 | 145 | 4.00 1.78, 6.22) | Adequate | 3 | No
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 30 | 66 | Simvastatin 40 | 34 | 4 | 169 | 1.23 (−2.43, 4.89) | Adequate | 5 | Yes
Farnier (2005)114 International Pharm. Fund Multicentre | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 179 | Simvastatin 10–20 | 186 | 6 | 123 | 0.75 (−2.01, 3.51) | Unclear | 5 | No
Combination – monotherapy, difference in mean percentage change from baseline (%):all statins, lower versus higher doses, all clinical populations
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 215 | Atorvastatin 20 | 207 | 6 | 124 | 2.20 (−0.02, 4.42) | unclear | 3 | No
Cruz- Fernandez (2005)115 International Pharm. Fund Multicenter | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 219 | Atorvastatin 10–20 | 225 | 6 | 122 | 2.80 (0.47, 5.13) | unclear | 4 | No
Brohet (2005)116 Europe Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 204 | Simvastatin 10–20 | 207 | 6 | 123 | −0.40 (−2.91, 2.11) | unclear | 5 | No
Pearson (2005)117 EASE North America Pharm. Fund Multicenter | Participants not meeting ATP III target LDL-c despite statin therapy | Mixed | 1940 | Mixed | 968 | 6 | 129 | 2.10 (1.20, 3.00) | Adequate | 4 | No
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals, DM subgroup | Mixed 10–80 | 88 | Mixed 10–80 | 94 | 12 | 136 | −0.80 (0.43, 2.09) | unclear | 3 | No
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinedione s, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 6–24 | 93 | −0.10 (−3.42, 3.22) | unclear | 3 | No
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 10–40 | 451 | Simvastatin 20 | 248 | 5 | 169 | 1.88 (0.06, 3.70) | unclear | 2 | No
Blagden (2007)140 COMPELL study North America Pharm. Fund Multicenter | Participants with CAD, statin naïve | Atorvastatin 10 | 72 | Atorvastatin 10 | 76 | 6 | 197 | −0.30 (−4.22, 3.62) | unclear | 4 | No
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 235 | Rosuvastatin 40 | 230 | 6 | 190 | 2.32 (−0.83, 5.47) | unclear | 1 | No
Constance (2007)194 International Pharm. fund | Participants with T2DM on low dose atorvastatin | Simvastatin 20–40 | 439 | Atorvastatin 20 | 218 | 6 | 94 | 0.20 (−2.05, 2.45) | Adequate | 3 | No
Kastelein (2008)42 ENHANCE International Pharm. fund | FHC, LDL-c > 210 mg/dL | Simvastatin 80 | 357 | Simvastatin 80 | 363.00 | 96 | 318 | 2.40 (−0.23, 5.03) | Adequate | 3 | No
Farnier (2005)114 International Pharm. Fund Multicentre | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 179 | Simvastatin 10–20 | 186 | 6 | 123 | 0.75 (−2.01, 3.51) | Unclear | 5 | No
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants with DM not at LDL-c ATP III goal off lipid lowering treatment | Simvastatin 10–80 | 212 | Atorvatstatin 10–80 | 201 | 6 | 178 | 2.6 (0.10, 5.10) | Adequate | 2 | no
Goldberg (2006_1)144 VYTAL North America Pharm. Fund Multicenter | Participants with type II DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dl – entered into diabetes subgroup analysis | Simvastatin 20 | 238 | Atorvatstatin 20 | 240 | 6 | 145 | 3.50 (1.28, 5.72) | Adequate | 3 | No
Goldberg (2006_2)144 VYTAL North America Pharm. Fund Multicenter | Participants with type II DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dl – entered into diabetes subgroup analysis | Simvastatin 40 | 242 | Atorvatstatin 40 | 241 | 6 | 145 | 4.00 (1.78, 6.22) | Adequate | 3 | No
Catapno (2006)193 North America Pharm. Fund Multicenter | Participants with DM | Simvastatin 20–80 | 186 | Rosuvastatin 10–40 | 181 | 6 | 173 | 0.7 (−1.52, 2.92) | Adequate | 3 | No
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10- year CHD risk > 20% | Atorvatstatin 40 | 277 | Atorvatstatin 80 | 279 | 6 | 89 | 0.5 (−1.16, 2.16) | Adequate | 5 | No
Pearson (2005)117 EASE North America Pharm. Fund Multicenter | Participants not meeting ATP III target LDL-c despite statin therapy -- subgroup of African descent | Mixed | 174 | Mixed | 93 | 6 | 129 | 3.30 (0.35, 6.25) | Adequate | 4 | No
Pearson (2005)117 EASE North America Pharm. Fund Multicenter | Participants not meeting ATP III target LDL-c despite statin therapy -- subgroup of Hispanic origin | Mixed | 94 | Mixed | 53 | 6 | 129 | 0.30 (−3.64, 4.24) | Adequate | 4 | No
Combination – monotherapy, difference in mean percentage change from baseline (%):all statins, lower versus higher doses, intensive lipid lowering populations and clinical subgroups
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 6–24 | 93 | −0.10 (−3.42, 3.22) | unclear | 3 | No

Table F-5

Surrogate outcome – TC:HDL-c ratio using ezetimibe plus statin therapy compared with statin monotherapy

Total cholesterol: high-density lipoprotein cholesterol ratio
Trial | Population | Combination Statin Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Mean Baseline LDL-c (mg/dL) | Combo-mono: mean difference (95% CI) | AAC | Jadad Score | ITTA
Combination – monotherapy, difference in mean percentage change from baseline: all statins, all doses, all clinical populations
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals | Simvastatin 80 | 344 | Simvastatin 80 | 78 | 12 | 136 | −20.30 (−26.78, − 13.82) | unclear | 3 | no
Goldberg (2004)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 323 | Simvastatin 10–80 | 322 | 12 | 175 | −10.90 (−13.01, −8.79) | Adequate | 5 | no
Ballantyne (2003)126 Ezetimibe Study Group International Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Atorvastatin 10–80 | 255 | Atorvastatin 10–80 | 248 | 12 | 183 | −10.10 (−12.53, −7.67) | unclear | 2 | no
Melani (2003)127 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Pravastatin 10–40 | 204 | Pravastatin 10–40 | 205 | 12 | 178 | −13.10 (−15.59, − 10.61) | Adequate | 4 | yes
Kerzner (2003)129 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Lovastatin 10–40 | 181 | Lovastatin 10–40 | 202 | 12 | 179 | −13.00 (−15.78, − 10.22) | unclear | 3 | yes
Davidson (2002)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10–80 | 253 | Simvastatin 10–80 | 249 | 12 | 179 | −11.16 (−13.38, −8.94) | Adequate | 4 | no
McKenney (2007_1)139 COMPELL study North America Pharm. Fund Multicenter | HC, heterogeneous 10-year CHD risk estimates | Simvastatin 40 | 72 | Rosuvastatin 40 | 73 | 12 | 197 | −4.00 (−7.91, −0.09) | unclear | 2 | no
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 215 | Atorvastatin 20 | 207 | 6 | 124 | −9.20 (−11.97, −6.43) | unclear | 3 | no
Cruz- Fernandez (2005)115 International Pharm. Fund Multicenter | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 219 | Atorvastatin 10–20 | 225 | 6 | 122 | −19.90 (−22.31, − 17.49) | unclear | 4 | no
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones , some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 6–24 | 93 | −13.50 (−18.22, −8.78) | unclear | 3 | no
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 235 | Rosuvastatin 40 | 230 | 6 | 190 | −10.36 (−12.62, −8.10) | unclear | 4 | no
Constance (2007)194 International Pharm. fund | Participants with T2DM on low dose atorvastatin | Simvastatin 20–40 | 439 | Atorvastatin 20 | 218 | 6 | 94 | −10.32 (−13.55, −7.10) | Adequate | 3 | no
Catapano (2006)193 North America Pharm. Fund Multicenter | Hypercholesterol emia, heterogeneous 10-year CHD risk estimates | Simvastatin 20–80 | 1427 | Rosuvastatin 10–40 | 1428 | 6 | 173 | −3.00 (−3.83, −2.17) | Adequate | 4 | no
Bays (2007)154 North America Pharm. Fund Multicenter | 1^0^ HC | Simvastatin 10–80 | 539 | Simvastatin 10–80 | 559 | 6–26 | 178 | −10.50 (−11.95, −9.05) | Adequate | 3 | no
Stein (2004)156 International Pharm. fund | 1° HC , LDL >= 130 mg/dL despite diet and atorvastatin 10 mg/day | Atorvastatin 40 | 278 | Atorvastatin 80 | 290 | 14 | 186 | −17.00 (−18.95, − 15.05) | unclear | 3 | yes
Conrad (2008)158 International Pharm. Fund Multicenter | Moderately high risk participants on atorvastatin 20 mg/day or statin naive and with LDL-c 100 mg/dL to <= 160 mg/dL | Atorvastatin 20 | 92 | Atorvastatin 40 | 92 | 6 | 119 | −13.00 (−17.61, −8.39) | Adequate | 5 | No
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10- year CHD risk > 20% | Atorvastatin 40 | 277 | Atorvastatin 80 | 279 | 6 | 89 | −10.40 (−12.62, −8.18) | Adequate | 5 | No
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants with DM not at LDL-c ATP III goal off lipid lowering treatment | Simvastatin 10–80 | 212 | Atorvastatin 10–80 | 201 | 6 | 178 | −7.50 (−9.85, − 5.15) | Adequate | 2 | no
Goldberg (2006_a)144 VYTAL North America Pharm. Fund Multicenter | Participants with type II DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dl | Simvastatin 20 | 240 | Atorvastatin 20 | 241 | 6 | 145 | 3.00 (0.78, 5.22) | Adequate | 3 | No
Goldberg (2006_b)144 VYTAL North America Pharm. Fund Multicenter | Participants with type II DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dl | Simvastatin 40 | 238 | Atorvastatin 40 | 242 | 6 | 145 | 1.90 (−0.32, 4.12) | Adequate | 3 | No
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | −9.88 (−14.64, − 5.12) | Adequate | 5 | Yes
Combination – monotherapy, difference in mean percentage change from baseline: all statins, lower versus higher doses, all clinical populations
Conrad (2008)158 International Pharm. Fund Multicenter | Moderately high risk participants on atorvastatin 20 mg/day or statin naive and with LDL-c 100 mg/dL to <= 160 mg/dL | Atorvastatin 20 | 92 | Atorvastatin 40 | 92 | 6 | 119 | −13.00 (− 17.61, −8.39) | Adequate | 5 | No
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones , some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 6–24 | 93 | −13.50 (−18.22, − 8.78) | unclear | 3 | no
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | −9.88 (− 14.64, −5.12) | Adequate | 5 | Yes
Bays (2004_1)154 North America Pharm. Fund Multicentre | Mixed 10 years CHD risk participants who were protocol compliant in a previous base study | Simvastatin 10 | 222 | Simvastatin 40 | 108 | 6–26 | 178 | −3.70 (−6.38, −1.02) | Adequate | 5 | No
Bays (2004_2)154 North America Pharm. Fund Multicentre | Mixed 10 years CHD risk participants who were protocol compliant in a previous base study | Simvastatin 20 | 106 | Simvastatin 80 | 224 | 6–26 | 178 | −1.40 (−4.12, 1.32) | Adequate | 5 | No
Goldberg (2004_1)48 Ezetimibe Study Group International Pharm. fund | Statin naïve, 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 10 | 87 | Simvastatin 40 | 90 | 12 | 175 | −3.30 (−7.22, 0.62) | Adequate | 5 | No
Goldberg (2004_2)48 Ezetimibe Study Group International Pharm. fund | Statin naïve, 1° HC, heterogeneous 10-year CHD risk estimates | Simvastatin 20 | 86 | Simvastatin 80 | 87 | 12 | 175 | −3.10 (−7.06, 0.86) | Adequate | 5 | No
Davidson (2002_1)130 Ezetimibe study group North America Pharm. Fund Multicentre | Mixed 10 years CHD risk | Simvastatin 10 | 67 | Simvastatin 40 | 64 | 12 | 179 | −6.82 (− 11.23, −2.41) | Adequate | 4 | No
Davidson (2002_2)130 Ezetimibe study group North America Pharm. Fund Multicentre | Mixed 10 years CHD risk | Simvastatin 20 | 68 | Simvastatin 80 | 66 | 12 | 179 | −1.01 (−5.38, 3.36) | Adequate | 4 | No
Combination – monotherapy, difference in mean percentage change from baseline: all statins, all doses, intensive lipid lowering populations and clinical subgroups
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 215 | Atorvastatin 20 | 207 | 6 | 124 | −9.20 (−11.97, − 6.43) | unclear | 3 | no
Cruz- Fernandez (2005)115 International Pharm. Fund Multicenter | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 219 | Atorvastatin 10–20 | 225 | 6 | 122 | −19.90 (−22.31, − 17.49) | unclear | 4 | no
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals, DM subgroup | Mixed 10–80 | 88 | Mixed 10–80 | 94 | 8 | 136 | −17.30 (−20.91, − 13.69) | unclear | 3 | no
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones , some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 6–24 | 93 | −13.50 (−18.22, − 8.78) | unclear | 3 | no
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 235 | Rosuvastatin 40 | 230 | 6 | 190 | −10.36 (−12.62, − 8.10) | unclear | 4 | no
Constance (2007)194 International Pharm. fund | Participants with T2DM on low dose atorvastatin | Simvastatin 20–40 | 439 | Atorvastatin 20 | 218 | 6 | 94 | −10.32 (−13.55, − 7.10) | Adequate | 3 | no
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10- year CHD risk > 20% | Atorvatstatin 40 | 277 | Atorvatstatin 80 | 279 | 6 | 89 | −10.40 (− 12.62, −8.18) | Adequate | 5 | No
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants with DM not at LDL-c ATP III goal off lipid lowering treatment | Simvastatin 10–80 | 212 | Atorvatstatin 10–80 | 201 | 6 | 178 | −7.50 (−9.85, −5.15) | Adequate | 2 | no
Catapno (2006)193 North America Pharm. Fund Multicenter | Participants with DM | Simvastatin 20–80 | 186 | Rosuvastatin 10–40 | 181 | 6 | 173 | −3.40 (−5.34, −1.46) | Adequate | 3 | No
Goldberg (2006_1)144 VYTAL North America Pharm. Fund Multicenter | Participants with type II DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dl | Simvastatin 20 | 238 | Atorvatstatin 20 | 240 | 6 | 145 | −6.70 (−8.92, −4.48) | Adequate | 3 | No
Goldberg (2006_2)144 VYTAL North America Pharm. Fund Multicenter | Participants with type II DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dl | Simvastatin 40 | 242 | Atorvatstatin 40 | 241 | 6 | 145 | −5.60 (−7.82, −3.38) | Adequate | 3 | No
Combination – monotherapy, difference in mean percentage change from baseline: all statins, lower versus higher doses, intensive lipid lowering populations and clinical subgroups
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 6–24 | 93 | −13.50 (−18.22, −8.78) | unclear | 3 | No

Table F-6

outcome – Non-HDL-c using ezetimibe plus statin therapy compared with statin monotherapy in participants with diabetes mellitus

Total cholesterol: high-density lipoprotein cholesterol ratio
Trial | Population | Combination Statin Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Mean Baseline LDL-c (mg/dL) | Combo- mono: mean difference (95% CI) | AAC | Jadad Score | ITTA
Combination – monotherapy, difference in mean percentage change from baseline
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals, DM subgroup | Mixed 10–80 | 88 | Mixed 10–80 | 94 | 8 | 136 | −23.80 (−27.96, −19.64) | unclear | 3 | no
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 6–24 | 93 | −18.30 (−23.98, −12.62) | unclear | 3 | no
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants with DM not at LDL-c ATP III goal off lipid lowering treatment | Simvastatin 10–80 | 212 | Atorvatstatin 10–80 | 201 | 6 | 178 | −8.30 (−11.07, − 5.53) | Adequate | 2 | no
Catapno (2006)193 North America Pharm. Fund Multicenter | Participants with DM | Simvastatin 20–80 | 186 | Rosuvastatin 10–40 | 181 | 6 | 173 | −4.20 (−6.42, − 1.98) | Adequate | 3 | No
Goldberg (2006_1)144 VYTAL North America Pharm. Fund Multicenter | Participants with type II DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dl | Simvastatin 20 | 238 | Atorvatstatin 20 | 240 | 6 | 145 | −6.70 (−8.92, − 4.48) | Adequate | 3 | No
Goldberg (2006_2)144 VYTAL North America Pharm. Fund Multicenter | Participants with type II DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dl | Simvastatin 40 | 242 | Atorvatstatin 40 | 241 | 6 | 145 | −5.60 (−7.82, − 3.38) | Adequate | 3 | No
Constance (2007)194 International Pharm. fund | Participants with T2DM on low dose atorvastatin | Simvastatin 20–40 | 439 | Atorvastatin 20 | 218 | 6 | 94 | −14.92 (−19.53, −10.31) | Adequate | 3 | No

Table F-7

Carotid intima-media thickness (CIMT) using ezetimibe plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Mean Baseline LDL-c (mg/dL) | Combo- mono: mean difference (95% CI) | AAC | Jadad Score | ITTA
Kastelein (2008)42 ENHANCE International Pharm. fund | FHC, LDL-c > 210 mg/dL | Simvastatin 80 | 322 | Simvastatin 80 | 320 | 96 | 318 | 0.01 (−0.01, 0.02) | Adequate | 3 | No

Table F-8

Adverse events and adherence to treatment using ezetimibe plus statin compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Trial Baseline LDL-c (mg/dL) | Combo/mono: number of participants with events Odds ratio (95% CI) | AAC | Jadad Score | ITTA
Relative probability of participants adhering to treatment: all statins, all doses, all clinical populations
Kastelein (2008)42 ENHANCE International Pharm. fund | FHC, LDL-c > 210 mg/dL | Simvastatin 80 | 357 | Simvastatin 80 | 363 | 96 | 318 | 300/283 1.49 (1.02, 2.17) | Adequate | 3 | no
Landray (2006)166 UK-HARP-II Europe Pharm. Fund Multicenter | Participants with renal disease and without definitive indication for cholesterol lowering | Simvastatin 20 | 102 | Simvastatin 20 | 101 | 24 | 119 | 87/92 0.57 (0.24, 1.36) | Adequate | 2 | yes
Ballantyne (2004_b)46 North America Pharm. Fund | HC, heterogeneous 10-year CHD risk estimates | Simvastatin 80 | 526 | Atorvastatin 80 | 262 | 24 | 542 | 432/223 0.80 (0.54, 1.21) | unclear | 3 | no
Stein (2004)156 International Pharm. fund | 1° HC, LDL >= 130 mg/dL despite diet and atorvastatin 10 mg/day | Atorvastatin 40 | 305 | Atorvastatin 80 | 316 | 14 | 186 | 278/290 0.92 (0.53, 1.62) | unclear | 3 | yes
Goldberg (2004)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 353 | Simvastatin 10–80 | 349 | 12 | 175 | 323/322 0.90 (0.52, 1.55) | Adequate | 5 | no
Melani (2003)127 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Pravastatin 10–40 | 204 | Pravastatin 10–40 | 205 | 12 | 178 | 184/192 0.62 (0.30, 1.29) | Adequate | 4 | yes
Davidson (2002_1)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 67 | Simvastatin 10 | 70 | 12 | 179 | 61/61 1.50 (0.50, 4.47) | Adequate | 4 | no
Davidson (2002_2)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 69 | Simvastatin 20 | 61 | 12 | 179 | 58/53 0.80 (0.30, 2.13) | Adequate | 4 | no
Davidson (2002_3)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 40 | 73 | Simvastatin 40 | 65 | 12 | 179 | 68/60 1.13 (0.31, 4.11) | Adequate | 4 | no
Davidson (2002_4)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 80 | 65 | Simvastatin 80 | 67 | 12 | 179 | 52/63 0.25 (0.08, 0.83) | Adequate | 4 | no
McKenney (2007_1)139 COMPELL study North America Pharm. Fund Multicenter | HC, heterogeneous 10-year CHD risk estimates | Simvastatin 40 | 72 | Rosuvastatin 40 | 73 | 12 | 197 | 71/61 13.97 (1.77, 110.52) | unclear | 2 | no
Cruz-Fernandez (2005)115 International Pharm. Fund Multicenter | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 229 | Atorvastatin 10–20 | 225 | 6 | 122 | 199/200 0.83 (0.47, 1.46) | unclear | 4 | no
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 239 | Rosuvastatin 40 | 230 | 6 | 190 | 232/219 1.66 (0.63, 4.37) | unclear | 1 | no
Patel (2006)143 Europe Pharm. Fund Multicenter | Participants with CAD not on recent lipid lowering drug treatment | Simvastatin 20 | 78 | Simvastatin 20 | 75 | 6 | 160 | 76/68 3.91 (0.79, 19.48) | unclear | 3 | no
Reckless (2008)149 INFORCE International Pharm. Fund Multicentre | CHD patients on previous stable statin dose | Simvastatin 40 | 207 | Double the previous (mixed) statin dose | 213 | 12 | 92.5 | 207/205 1.01 (0.32, 3.18) | Adequate | 2 | No
Relative probability of participants adhering to treatment - all statins, lower versus higher doses, all clinical populations
Davidson (2002_5)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 67 | Simvastatin 40 | 65 | 12 | 179 | 61/60 0.85 (0.25, 2.93) | Adequate | 4 | no
Davidson (2002_6)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 69 | Simvastatin 80 | 67 | 12 | 179 | 58/63 0.33 (0.10, 1.11) | Adequate | 4 | no
Relative probability of participants experiencing an adverse event: all statins, all doses, all clinical populations
Ballantyne (2003)126 Ezetimibe Study Group International Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Atorvastatin 80 | 201 | Atorvastatin 80 | 45 | 52 | 183 | 142/30 1.20 (0.60, 2.40) | unclear | 2 | no
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals | Simvastatin 80 | 355 | Simvastatin 80 | 78 | 48 | 136 | 265/56 1.16 (0.67, 2.00) | unclear | 3 | no
Goldberg (2004)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 539 | Simvastatin 20–80 | 229 | 48 | 175 | 393/159 1.19 (0.84, 1.66) | Adequate | 5 | no
Ballantyne (2004_b)46 North America Pharm. Fund | HC, heterogeneous 10- year CHD risk estimates | Simvastatin 80 | 432 | Atorvastatin 80 | 223 | 24 | 542 | 349/187 0.81 (0.53, 1.24) | unclear | 3 | no
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 10–40 | 457 | Simvastatin 40 | 253 | 23 | 169 | 277/168 0.78 (0.56, 1.07) | unclear | 2 | no
Bays (2004)154 North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 544 | Simvastatin 10–80 | 560 | 14–26 | 178 | 190/193 1.02 (0.80, 1.31) | Adequate | 5 | no
Stein (2004)156 International Pharm. fund | 1° HC, LDL >= 130 mg/dL despite diet and atorvastatin 10 mg/day | Atorvastatin 40 | 305 | Atorvastatin 80 | 316 | 14 | 186 | 193/184 1.24 (0.90, 1.71) | unclear | 3 | yes
Rodney (2006)111 Pharm. Fund Multicenter | African descent, 1° HC | Simvastatin 20 | 124 | Simvastatin 20 | 123 | 12 | 176 | 71/69 1.05 (0.63, 1.73) | Adequate | 5 | no
Melani (2003)127 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Pravastatin 10–40 | 204 | Pravastatin 10–40 | 205 | 12 | 178 | 134/129 1.13 (0.75, 1.69) | Adequate | 4 | yes
Kerzner (2003)129 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Lovastatin 10–40 | 192 | Lovastatin 10–40 | 220 | 12 | 179 | 122/141 0.98 (0.65, 1.46) | unclear | 3 | yes
Davidson (2002)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 268 | Simvastatin 10–80 | 261 | 12 | 179 | 185/188 0.87 (0.60, 1.26) | Adequate | 4 | no
Shankar (2007)168 Asia Pharm. Fund Multicenter | South Asians, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 114 | Simvastatin 10 | 116 | 12 | 127 | 39/38 1.07 (0.62, 1.85) | unclear | 2 | yes
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 221 | Atorvastatin 20 | 214 | 6 | 124 | 44/51 0.79 (0.50, 1.25) | unclear | 3 | no
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 238 | Rosuvastatin 40 | 230 | 6 | 190 | 75/77 0.91 (0.62, 1.35) | unclear | 1 | no
Goldberg (2006)144 VYTAL North America Pharm. Fund Multicenter | T2DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dL | Simvastatin 20–40 | 494 | Atorvastatin 10–40 | 732 | 6 | 145 | 106/176 0.86 (0.66, 1.13) | Adequate | 3 | no
Geiss (2005)119 | Severe HC LDL-c>190 all on LDL-c- apheresis | Mixed 5–20 | 20 | Mixed 5–20 | 20 | 2 | | 0/0 0.00 (0.00, 0.00) | unclear | 2 | no
Kosoglou (2004)124 Europe Pharm. Fund Single centre | Healthy participants with LDL-c >= 130 mg/dL and BMI < 31kg/m2. Low risk | Rosuvastatin 10 | 12 | Rosuvastatin 10 | 12 | 23 | 158 | 11/9 3.67 (0.32, 41.59) | unclear | 2 | yes
Reckless (2008)149 INFORCE International Pharm. Fund Multicentre | CHD patients on previous stable statin dose | Simvastatin 40 | 213 | Double the previous (mixed) statin dose | 211 | 12 | 92.5 | 102/96 (0.75, 1.61) | Adequate | 2 | No
Roeters van Lennep (2008)151 EASEGO Europe Pharm. Fund Multicentre | CHD and/or controlled type II DM patients not on target LDL-c despite prior low dose simvastatin or atorvastatin therapy | Simvastatin 20 | 178 | Simvastatin 40 or atorvastatin 20 | 189 | 12 | 115 | 64/66 1.05 (0.68, 1.61) | Unclear | 3 | Yes
Dagli (2007)187 Europe Single center | CHD or risk equivalent with off treatment LDL-c > 210 mg/dL | Pravastatin 10 | 50 | Pravastatin 40 | 50 | 24 | 162 | 3/6 0.47 (0.11, 1.99) | Unclear | 2 | Yes
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10-year CHD risk > 20% | Atorvastatin 40 | 286 | Atorvastatin 80 | 289 | 6 | 89 | 63/61 1.06 (0.71, 1.57) | Adequate | 5 | No
Relative probability of participants experiencing an adverse event: all statins, all doses, all clinical populations
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 20 | 109 | Simvastatin 40 | 253 | 23 | 169 | 74/168 1.07 (0.66, 1.73) | unclear | 2 | no
Relative probability of participants withdrawing from trial due to an adverse event
Kastelein (2008)42 ENHANCE International Pharm. fund | FHC LDL-c>190 | Simvastatin 80 | 357 | Simvastatin 80 | 363 | 96 | 318 | 29/34 0.86 (0.51, 1.44) | Adequate | 3 | no
Ballantyne (2003)126 Ezetimibe Study Group International Pharm. Fund Multicenter | 1° HC heterogeneous 10- year CHD risk estimates | Atorvastatin 80 | 201 | Atorvastatin 80 | 45 | 52 | 183 | 19/3 1.46 (0.41, 5.17) | unclear | 2 | no
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals | Simvastatin 80 | 355 | Simvastatin 80 | 78 | 48 | 136 | 26/8 0.69 (0.30, 1.59) | unclear | 3 | no
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 104 | Simvastatin 40 | 110 | 24 | 93 | 2/5 0.41 (0.08, 2.17) | unclear | 3 | no
Ballantyne (2004_b)46 North America Pharm. Fund | HC, heterogeneous 10-year CHD risk estimates | Simvastatin 80 | 526 | Atorvastatin 80 | 262 | 24 | 542 | 46/14 1.70 (0.92, 3.15) | unclear | 3 | no
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 10–40 | 457 | Simvastatin 40 | 253 | 23 | 169 | 23/14 0.90 (0.46, 1.79) | unclear | 2 | no
Bays (2004)154 North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 544 | Simvastatin 10–80 | 560 | 14–26 | 178 | 14/12 1.21 (0.55, 2.63) | Adequate | 5 | no
Stein (2004)156 International Pharm. fund | 1° HC, LDL >= 130 mg/dL despite diet and atorvastatin 10 mg/day | Atorvastatin 40 | 305 | Atorvastatin 80 | 316 | 14 | 186 | 13/14 0.96 (0.44, 2.08) | unclear | 3 | yes
Rodney (2006)111 Pharm. Fund Multicenter | African descent, 1° HC | Simvastatin 20 | 124 | Simvastatin 20 | 123 | 12 | 176 | 2/1 2.00 (0.18, 22.35) | Adequate | 5 | no
Goldberg (2004)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 353 | Simvastatin 10–80 | 349 | 12 | 175 | 16/7 2.32 (0.94, 5.71) | Adequate | 5 | no
Melani (2003)127 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Pravastatin 10–40 | 204 | Pravastatin 10–40 | 205 | 12 | 178 | 9/3 3.11 (0.83, 11.65) | Adequate | 4 | yes
Kerzner (2003)129 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Lovastatin 10–40 | 192 | Lovastatin 10–40 | 220 | 12 | 179 | 9/10 1.03 (0.41, 2.60) | unclear | 3 | yes
Davidson (2002_1)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 67 | Simvastatin 10 | 70 | 12 | 179 | 2/4 0.51 (0.09, 2.87) | Adequate | 4 | no
Davidson (2002_2)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 69 | Simvastatin 20 | 61 | 12 | 179 | 7/6 1.03 (0.33, 3.27) | Adequate | 4 | no
Davidson (2002_3)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 40 | 73 | Simvastatin 40 | 65 | 12 | 179 | 3/2 1.35 (0.22, 8.34) | Adequate | 4 | no
Davidson (2002_4)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 80 | 65 | Simvastatin 80 | 67 | 12 | 179 | 8/2 4.56 (0.93, 22.36) | Adequate | 4 | no
Gagne (2002)132 Ezetimibe Study Group International Pharm. fund | Homozygous FHC, 7 (14%) participants between 12–18 years of age | Mixed 40–80 | 33 | Mixed 80 | 17 | 12 | 309 | 2/0 2.78 (0.13, 61.17) | unclear | 3 | no
Shankar (2007)168 Asia Pharm. Fund Multicenter | South Asians, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 114 | Simvastatin 10 | 116 | 12 | 127 | 0/0 | unclear | 2 | yes
Stein (2008)148 International Pharm. fund | HC, Participants with documented statin associated muscle related side effects | Fluvastatin 80 | 64 | Fluvastatin 80 | 69 | 12 | 174 | 5/6 0.89 (0.26, 3.07) | Adequate | 5 | yes
Constance (2007) 194 International Pharm. fund | Participants with T2DM on low dose atorvastatin | Simvastatin 20–40 | 442 | Atorvastatin 20 | 219 | 8 | 94 | 10/2 2.51 (0.55, 11.56) | Adequate | 3 | no
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 217 | Atorvastatin 20 | 210 | 6 | 124 | 1/0 2.92 (0.12, 72.00) | unclear | 3 | no
Cruz-Fernandez (2005)115 International Pharm. Fund Multicenter | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 220 | Atorvastatin 10–20 | 230 | 6 | 122 | 2/1 2.10 (0.19, 23.34) | unclear | 4 | no
Brohet (2005)116 Europe Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 208 | Simvastatin 10–20 | 210 | 6 | 123 | 2/0 5.10 (0.24, 106.81) | unclear | 5 | no
Blagden (2007)140 Europe Pharm. Fund Multicenter | Participants with CAD, statin naïve | Atorvastatin 10 | 72 | Atorvastatin 10 | 76 | 6 | 157 | 6/1 6.82 (0.80, 58.11) | unclear | 4 | yes
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 238 | Rosuvastatin 40 | 230 | 6 | 190 | 6/3 1.96 (0.48, 7.92) | unclear | 1 | no
Patel (2006)143 Europe Pharm. Fund Multicenter | Participants with CAD not on recent lipid lowering drug treatment | Simvastatin 20 | 77 | Simvastatin 20 | 75 | 6 | 160 | 5/1 5.14 (0.59, 45.07) | unclear | 3 | no
Goldberg (2006)144 VYTAL North America Pharm. Fund Multicenter | T2DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dL | Simvastatin 20–40 | 494 | Atorvastatin 10–40 | 732 | 6 | 145 | 4/11 0.54 (0.17, 1.69) | Adequate | 3 | no
Kosoglou (2002)106 North America Pharm. Fund Single centre | Healthy male participants. Low risk | Simvastatin 10 | 12 | Simvastatin 10 | 12 | 2 | 169 | 1/0 3.26 (0.12, 88.35) | unclear | 2 | no
Roeters van Lennep (2008)151 EASEGO Europe Pharm. Fund Multicentre | CHD and/or controlled T2DM patients not on target LDL-c despite prior low dose simvastatin or atorvastatin therapy | Simvastatin 20 | 178 | Mixed 20–40 | 189 | 12 | 115 | 10/7 1.55 (0.58, 4.16) | Unclear | 3 | No
Dagli (2007)187 Europe Single center | CHD or risk equivalent with off treatment LDL-c > 210 mg/dL | Pravastatin 10 | 50 | Pravastatin 40 | 50 | 24 | 162 | 0/0 | Unclear | 2 | Yes
Conrad (2008)158 International Pharm. Fund Multicenter | Moderately high risk participants on atorvastatin 20 mg/day or statin naive and with LDL-c 100 mg/dL to <= 160 mg/dL | Atorvastatin 20 | 96 | Atorvastatin 40 | 98 | 6 | 119 | 0/2 0.20 (0.01, 4.22) | Adequate | 5 | No
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10-year CHD risk > 20% | Atorvastatin 40 | 286 | Atorvastatin 80 | 289 | 6 | 89 | 4/6 0.67 (0.19, 2.40) | Adequate | 5 | No
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants with DM not at LDL-c ATP III goal off lipid lowering treatment | Simvastatin 10–80 | 220 | Atorvastatin 10–80 | 206 | 6 | 178 | 4/2 1.89 (0.34, 10.42) | Adequate | 2 | no
Catapno (2006)193 North America Pharm. Fund Multicenter | Participants with DM | Simvastatin 20–80 | 190 | Rosuvastatin 10–40 | 185 | 6 | 173 | 6/6 0.97 (0.31, 3.07) | Adequate | 3 | No
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | 6/1 3.30 (0.38, 28.59) | Adequate | 5 | Yes
Relative probability of participants withdrawing from trial due to an adverse event: all statins, lower versus higher doses, all clinical populations
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 104 | Simvastatin 40 | 110 | 24 | 93 | 2/5 0.41 (0.08, 2.17) | unclear | 3 | no
Davidson (2002_1)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 67 | Simvastatin 40 | 65 | 12 | 179 | 2/2 0.41 (0.08, 2.17) | Adequate | 4 | no
Davidson (2002_2)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 360 | Simvastatin 80 | 253 | 12 | 179 | 18/14 0.90 (0.44, 1.84) | Adequate | 4 | no
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 10–20 | 360 | Simvastatin 40 | 253 | 23 | 169 | 18/14 0.90 (0.44, 1.84) | unclear | 2 | no
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | 6/1 3.30 (0.38, 28.59) | Adequate | 5 | Yes
Relative probability of participants experiencing elevated serum AST and/or ALT 3 times ULN and/or hepatitis: all statins, all doses, all clinical populations
Ballantyne (2003)126 Ezetimibe Study Group International Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Atorvastatin 80 | 201 | Atorvastatin 80 | 45 | 52 | 183 | 1/0 0.68 (0.03, 16.98) | unclear | 2 | no
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals | Simvastatin 80 | 296 | Simvastatin 80 | 57 | 48 | 136 | 1/0 0.58 (0.02, 14.51) | unclear | 3 | no
Goldberg (2004)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 530 | Simvastatin 20–80 | 227 | 48 | 175 | 15/1 6.58 (0.86, 50.13) | Adequate | 5 | no
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 24 | 93 | 1/1 1.04 (0.06, 16.84) | unclear | 3 | no
Ballantyne (2004)46 North America Pharm. Fund Multicenter | HC, heterogeneous 10-year CHD risk estimates | Simvastatin 80 | 511 | Atorvastatin 80 | 252 | 24 | 542 | 11/6 0.90 (0.33, 2.47) | unclear | 3 | no
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 10–40 | 451 | Simvastatin 40 | 248 | 23 | 169 | 2/0 2.76 (0.13, 57.80) | unclear | 2 | no
Bays (2004)154 North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 540 | Simvastatin 10–80 | 559 | 14–26 | 178 | 8/7 1.19 (0.43, 3.29) | Adequate | 5 | no
Stein (2004)156 International Pharm. fund | 1° HC, LDL >= 130 mg/dL despite diet and atorvastatin 10 mg/day | Atorvastatin 40 | 305 | Atorvastatin 80 | 316 | 14 | 186 | 3/1 3.13 (0.32, 30.25) | unclear | 3 | yes
Rodney (2006)111 Pharm. Fund Multicenter | African descent, 1° HC | Simvastatin 20 | 124 | Simvastatin 20 | 123 | 12 | 176 | 0/0 | Adequate | 5 | no
Melani (2003)127 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Pravastatin 10–40 | 204 | Pravastatin 10–40 | 205 | 12 | 178 | 2/1 2.02 (0.18, 22.45) | Adequate | 4 | yes
Kerzner (2003)129 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Lovastatin 10–40 | 192 | Lovastatin 10–40 | 220 | 12 | 179 | 1/0 3.45 (0.14, 85.29) | unclear | 3 | yes
Gagne (2002)132 Ezetimibe Study Group International Pharm. fund | Homozygous FHC, 7 (14%) participants between 12–18 years of age | Mixed 40–80 | 29 | Mixed 80 | 16 | 12 | 309 | 2/0 3.00 0.14, 66.40 | unclear | 3 | no
Stein (2008)148 International Pharm. fund | HC, Participants with documented statin associated muscle related side effects | Fluvastatin 80 | 64 | Fluvastatin 80 | 69 | 12 | 174 | 1/1 1.08 (0.07, 17.62) | Adequate | 5 | yes
Davidson (2002_1)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 61 | Simvastatin 10 | 61 | 12 | 179 | 0/0 | Adequate | 4 | no
Davidson (2002_2)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 58 | Simvastatin 20 | 53 | 12 | 179 | 1/1 0.91 (0.06, 14.96) | Adequate | 4 | no
Davidson (2002_3)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 40 | 68 | Simvastatin 40 | 60 | 12 | 179 | 4/0 8.44 (0.45, 160.12) | Adequate | 4 | no
Davidson (2002_4)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 80 | 52 | Simvastatin 80 | 63 | 12 | 179 | 1/1 1.22 (0.07, 19.92) | Adequate | 4 | no
Constance (2007) 194 International Pharm. fund | Participants with T2DM on low dose atorvastatin | Simvastatin 20–40 | 442 | Atorvastatin 20 | 219 | 8 | 94 | 3/1 1.49 (0.15, 14.41) | Adequate | 3 | no
Cruz-Fernandez (2005)115 International Pharm. Fund Multicenter | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 218 | Atorvastatin 10–20 | 230 | 6 | 122 | 1/0 3.18 (0.13, 78.46) | unclear | 4 | no
Brohet (2005)116 Europe Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 208 | Simvastatin 10–20 | 210 | 6 | 123 | 0/0 | unclear | 5 | no
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants not on ATP III target LDL- c | Simvastatin 10–80 | 933 | Atorvastatin 10–80 | 939 | 6 | 178 | 1/11 0.09 (0.01, 0.70) | Adequate | 2 | no
Blagden (2007)140 Europe Pharm. Fund Multicenter | Participants with CAD, statin naïve | Atorvastatin 10 | 72 | Atorvastatin 10 | 76 | 6 | 157 | 0/0 | unclear | 4 | yes
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 238 | Rosuvastatin 40 | 230 | 6 | 190 | 3/0 6.85 (0.35, 133.38) | unclear | 1 | no
Goldberg (2006)144 VYTAL North America Pharm. Fund Multicenter | T2DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dL | Simvastatin 20–40 | 494 | Atorvastatin 10–40 | 732 | 6 | 145 | 0/3 0.21 (0.01, 4.09) | Adequate | 3 | no
Catapano (2006)193 North America Pharm. Fund Multicenter | Hypercholesterolemia, heterogeneous 10- year CHD risk estimates | Simvastatin 20–80 | 1437 | Rosuvastatin 10–40 | 1447 | 6 | 173 | 9/3 3.03 (0.82, 11.23) | Adequate | 3 | no
Geiss (2005)119 | Severe HC LDL- c>190 all on LDL- c-apheresis | Mixed 5–20 | 20 | Mixed 5–20 | 20 | 5 | | 0/0 | unclear | 2 | no
Kosoglou (2002)106 North America Pharm. Fund Single centre | Healthy male participants. Low risk | Simvastatin 10 | 12 | Simvastatin 10 | 12 | 2 | 169 | 0/0 | unclear | 2 | no
Reckless (2008)149 INFORCE International Pharm. Fund Multicentre | CHD patients on previous stable statin dose | Simvastatin 40 | 204 | Double the previous (mixed) statin dose | 203 | 12 | 92.5 | 6/7 0.85 (0.28, 2.56) | Adequate | 2 | No
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10-year CHD risk > 20% | Atorvastatin 40 | 281 | Atorvastatin 80 | 283 | 6 | 89 | 1/1 1.01 (0.06, 16.14) | Adequate | 5 | No
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | 1/0 4.55 (0.07, 285/04) | Adequate | 5 | Yes
Relative probability of participants experiencing elevated serum AST and/or ALT 3 times ULN and/or hepatitis: all statins, lower versus higher doses, all clinical populations
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 107 | 24 | 93 | 1/1 1.04 (0.06, 16.84) | unclear | 3 | no
Goldberg (2004_1)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 134 | Simvastatin 40 | 77 | 48 | 175 | 1/0 1.74 (0.07, 43.28) | Adequate | 5 | no
Goldberg (2004_2)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 135 | Simvastatin 80 | 73 | 48 | 175 | 1/1 0.54 (0.03, 8.72) | Adequate | 5 | no
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 10–20 | 354 | Simvastatin 40 | 248 | 23 | 169 | 1/0 2.11 (0.09, 51.98) | unclear | 2 | no
Davidson (2002_5)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 61 | Simvastatin 40 | 60 | 12 | 179 | 0/0 | Adequate | 4 | no
Davidson (2002_6)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 20 | 58 | Simvastatin 80 | 63 | 12 | 179 | 1/1 1.09 (0.07, 17.80) | Adequate | 4 | no
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | 1/0 4.55 (0.07, 285/04) | Adequate | 5 | Yes
Relative probability of participants experiencing myalgia: all statins, all doses, all clinical populations
Ballantyne (2003)126 Ezetimibe Study Group International Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Atorvastatin 80 | 201 | Atorvastatin 80 | 45 | 52 | 183 | 1/0 0.68 (0.03, 16.98) | unclear | 2 | no
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals | Simvastatin 80 | 296 | Simvastatin 80 | 57 | 48 | 136 | 1/0 0.58 (0.02, 14.51) | unclear | 3 | no
Goldberg (2004)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 539 | Simvastatin 20–80 | 229 | 48 | 175 | 15/7 0.91 (0.37, 2.26) | Adequate | 5 | no
Bays (2004)154 North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 544 | Simvastatin 10–80 | 560 | 14–26 | 178 | 2/5 0.41 (0.08, 2.12) | Adequate | 5 | no
Stein (2004)156 International Pharm. fund | 1° HC, LDL >= 130 mg/dL despite diet and atorvastatin 10 mg/day | Atorvastatin 40 | 305 | Atorvastatin 80 | 316 | 14 | 186 | 24/28 0.88 (0.50, 1.55) | unclear | 3 | yes
Davidson (2002)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 139 | Simvastatin 10–80 | 237 | 12 | 179 | 0/1 0.57 (0.02, 13.97) | Adequate | 4 | no
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 221 | Atorvastatin 20 | 214 | 6 | 124 | 6/5 1.17 (0.35, 3.88) | unclear | 3 | no
Farnier (2005)114 International Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 181 | Simvastatin 10–20 | 191 | 6 | 123 | 3/4 0.79 (0.17, 3.57) | unclear | 5 | no
Blagden (2007)140 Europe Pharm. Fund Multicenter | Participants with CAD, statin naïve | Atorvastatin 10 | 72 | Atorvastatin 10 | 76 | 6 | 157 | 3/0 7.71 (0.39, 151.84) | unclear | 4 | yes
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 238 | Rosuvastatin 40 | 230 | 6 | 190 | 7/7 0.97 (0.33, 2.80) | unclear | 1 | no
Kosoglou (2004_a)124 Europe Pharm. Fund Single centre | Healthy participants with LDL-c >= 130 mg/dL and BMI < 31kg/m2. Low risk | Rosuvastatin 10 | 12 | Rosuvastatin 10 | 12 | 2 | 158 | 2/2 1.00 (0.12, 8.56) | unclear | 2 | yes
Kosoglou (2004_b)181 North America Pharm. Fund Single centre | Healthy participants of European descent with LDL-c >= 130 mg/dL and BMI < 31kg/m2. Low risk | Lovastatin 20–40 | 15 | Lovastatin 20 | 8 | 2 | 177 | 1/0 1.76 (0.06, 48.19) | unclear | 1 | yes
Kosoglou (2002)106 North America Pharm. Fund Single centre | Healthy male participants. Low risk | Simvastatin 10 | 12 | Simvastatin 10 | 12 | 2 | 169 | 1/0 3.26 (0.12, 88.35) | unclear | 2 | no
Berthold (2006)109 Europe Pharm. Fund Single centre | Healthy male participants. Low risk | Simvastatin 40 | 24 | Simvastatin 40 | 24 | 2 | 114 | 0/0 | unclear | 2 | yes
Chenot (2007)146 Europe Single centre | Tertiary care patients with acute MI | Simvastatin 40 | 20 | Simvastatin 40 | 20 | 1 | 146 | 0/0 | unclear | 1 | yes
Relative probability of participants experiencing CPK greater than 10 times the upper limit of normal: all statins, all doses, all clinical populations
Kastelein (2008)42 ENHANCE International Pharm. fund | FHC, LDL-c > 210 mg/dL | Simvastatin 80 | 356 | Simvastatin 80 | 360 | 96 | 318 | 4/8 0.50 (0.15, 1.68) | Adequate | 3 | no
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals | Simvastatin 80 | 296 | Simvastatin 80 | 57 | 48 | 136 | 0/0 | unclear | 3 | no
Landray (2006)166 UK-HARP-II Europe Pharm. Fund Multicenter | Participants with renal disease and without definitive indication for cholesterol lowering | Simvastatin 20 | 102 | Simvastatin 20 | 101 | 24 | 119 | 0/0 | Adequate | 2 | yes
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 110 | 24 | 93 | 1/0 3.23 (0.13, 80.29) | unclear | 3 | no
Ballantyne (2004)46 North America Pharm. Fund Multicenter | HC, heterogeneous 10-year CHD risk estimates | Simvastatin 80 | 510 | Atorvastatin 80 | 252 | 24 | 180 | 3/0 3.48 (0.18, 67.68) | unclear | 3 | no
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 10–40 | 451 | Simvastatin 40 | 248 | 23 | 169 | 1/2 0.27 (0.02, 3.03) | unclear | 2 | no
Bays (2004)154 North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 540 | Mixed 10–80 | 559 | 14–26 | 178 | 1/1 1.04 (0.06, 16.59) | Adequate | 5 | no
Stein (2004)156 International Pharm. fund | 1° HC, LDL >= 130 mg/dL despite diet and atorvastatin 10 mg/day | Atorvastatin 40 | 305 | Atorvastatin 80 | 316 | 14 | 186 | 0/1 0.34 (0.01, 8.48) | unclear | 3 | yes
Rodney (2006)111 Pharm. Fund Multicenter | African descent, 1° HC | Simvastatin 20 | 124 | Simvastatin 20 | 123 | 12 | 176 | 0/1 0.33 (0.01, 8.13) | Adequate | 5 | no
Goldberg (2004)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 323 | Simvastatin 10–80 | 322 | 12 | 175 | 2/1 2.00 (0.18, 22.17) | Adequate | 5 | no
Ballantyne (2003)126 Ezetimibe Study Group International Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Atorvastatin 10–80 | 248 | Atorvastatin 10–80 | 235 | 12 | 183 | 1/0 2.85 (0.12, 70.42) | unclear | 2 | no
Melani (2003)127 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Pravastatin 10–40 | 204 | Pravastatin 10–40 | 205 | 12 | 178 | 0/2 0.20 (0.01, 4.17) | Adequate | 4 | yes
Kerzner (2003)129 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Lovastatin 10–40 | 192 | Lovastatin 10–40 | 220 | 12 | 179 | 0/0 | unclear | 3 | yes
Davidson (2002)130 Ezetimibe study group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 239 | Simvastatin 10–80 | 237 | 12 | 179 | 0/2 0.20 (0.01, 4.12) | Adequate | 4 | no
McKenney (2007_1)139 COMPELL study North America Pharm. Fund Multicenter | HC, heterogeneous 10-year CHD risk estimates | Simvastatin 40 | 72 | Rosuvastatin 40 | 73 | 12 | 197 | 0/0 | unclear | 2 | no
Shankar (2007)168 Asia Pharm. Fund Multicenter | South Asians, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 114 | Simvastatin 10 | 116 | 12 | 127 | 0/1 0.34 (0.01, 8.34) | unclear | 2 | yes
Stein (2008)148 International Pharm. fund | HC, Participants with documented statin associated muscle related side effects | Fluvastatin 80 | 64 | Fluvastatin 80 | 69 | 12 | 174 | 0/0 | Adequate | 5 | yes
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 217 | Atorvastatin 20 | 210 | 6 | 124 | 0/0 | unclear | 3 | no
Farnier (2005)114 International Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 181 | Simvastatin 10–20 | 191 | 6 | 123 | 1/0 3.18 (0.13, 78.64) | unclear | 5 | no
Cruz-Fernandez (2005)115 International Pharm. Fund Multicenter | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 220 | Atorvastatin 10–20 | 230 | 6 | 122 | 0/0 | unclear | 4 | no
Brohet (2005)116 Europe Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 208 | Simvastatin 10–20 | 210 | 6 | 123 | 0/0 | unclear | 5 | no
Pearson (2005)117 EASE North America Pharm. Fund Multicenter | Participants not meeting ATP III target LDL-c despite statin therapy | Mixed | 1965 | Mixed | 992 | 6 | 129 | 0/0 | Adequate | 4 | no
Ballantyne (2005)118 VYVA North America Pharm. Fund Multicenter | Participants not on ATP III target LDL- c | Simvastatin 10–80 | 933 | Atorvastatin 10–80 | 939 | 6 | 178 | 0/1 0.34 (0.01, 8.24) | Adequate | 2 | no
Blagden (2007)140 Europe Pharm. Fund Multicenter | Participants with CAD, statin naïve | Atorvastatin 10 | 72 | Atorvastatin 10 | 76 | 6 | 157 | 0/0 | unclear | 4 | yes
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 238 | Rosuvastatin 40 | 230 | 6 | 190 | 0/0 | unclear | 1 | no
Goldberg (2006)144 VYTAL North America Pharm. Fund Multicenter | T2DM, hemoglobin A-1c < 8.5% and LDL-c > 100 mg/dL | Atorvastatin 20–40 | 494 | Atorvastatin 10–40 | 732 | 6 | 145 | 0/0 | Adequate | 3 | no
Catapano (2006)193 North America Pharm. Fund Multicenter | Hypercholesterolemia, heterogeneous 10- year CHD risk estimates | Simvastatin 20–80 | 1437 | Rosuvastatin 10–40 | 1447 | 6 | 173 | 4/1 4.04 (0.45, 36.16) | Adequate | 3 | no
Geiss (2005)119 | Severe HC LDL- c>190 all on LDL- c-apheresis | Mixed 5–20 | 20 | Mixed 5–20 | 20 | 5 | | 0/0 | unclear | 2 | no
Kosoglou (2002)106 North America Pharm. Fund Single centre | Healthy male participants. Low risk | Simvastatin 10 | 12 | Simvastatin 10 | 12 | 2 | 169 | 0/0 | unclear | 2 | no
Reckless (2008)149 INFORCE International Pharm. Fund Multicentre | CHD patients on previous stable statin dose | Simvastatin 40 | 213 | Double the previous (mixed) statin dose | 211 | 12 | 92.5 | 0/0 | Adequate | 2 | No
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10-year CHD risk > 20% | Atorvastatin 40 | 281 | Atorvastatin 80 | 283 | 6 | 89 | 0/0 | Adequate | 5 | No
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | 0/0 | Adequate | 5 | Yes
Relative probability of participants experiencing CPK greater than 10 times the upper limit of normal - all statins, lower versus higher doses, all clinical populations
Gaudiani (2005)121 North America Pharm. Fund Multicenter | Participants with T2DM on stable thiazolidinediones, some of whom had previously completed a simvastatin trial, with LDL-c > 100 mg/dL | Simvastatin 20 | 103 | Simvastatin 40 | 110 | 24 | 93 | 1/0 3.23 (0.13, 80.29) | unclear | 3 | no
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 10–20 | 354 | Simvastatin 40 | 248 | 23 | 169 | 0/2 0.14 (0.01, 2.91) | unclear | 2 | no
Relative probability of participants experiencing rhabdomyolysis (investigator defined) : all statins, all doses, all clinical populations
Masana (2005)167 Ezetimibe study group International Pharm. fund | Participants on stable statin treatment but not on ATP II LDL-c goals | Simvastatin 80 | 296 | Simvastatin 80 | 57 | 48 | 136 | 0/0 | unclear | 3 | no
Goldberg (2004)48 Ezetimibe Study Group International Pharm. fund | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 539 | Simvastatin 20–80 | 229 | 48 | 175 | 0/0 | Adequate | 5 | no
Ballantyne (2004)46 North America Pharm. Fund Multicenter | HC, heterogeneous 10-year CHD risk estimates | Simvastatin 80 | 432 | Atorvastatin 80 | 223 | 24 | 180 | 0/0 | unclear | 3 | no
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 10–40 | 457 | Simvastatin 40 | 253 | 23 | 169 | 0/0 | unclear | 2 | no
Bays (2004)154 North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Simvastatin 10–80 | 544 | Simvastatin 10–80 | 560 | 14–26 | 178 | 0/0 | Adequate | 5 | no
Stein (2004)156 International Pharm. fund | 1° HC, LDL >= 130 mg/dL despite diet and atorvastatin 10 mg/day | Atorvastatin 40 | 305 | Atorvastatin 80 | 316 | 14 | 186 | 0/0 | unclear | 3 | yes
Rodney (2006)111 Pharm. Fund Multicenter | African descent, 1° HC | Simvastatin 20 | 124 | Simvastatin 20 | 123 | 12 | 176 | 0/0 | Adequate | 5 | no
Kerzner (2003)129 Ezetimibe Study Group North America Pharm. Fund Multicenter | 1° HC, heterogeneous 10- year CHD risk estimates | Lovastatin 10–40 | 192 | Lovastatin 10–40 | 220 | 12 | 179 | 0/0 | unclear | 3 | yes
Gagne (2002)132 Ezetimibe Study Group International Pharm. fund | Homozygous FHC, 7 (14%) participants between 12–18 years of age | Mixed 40–80 | 29 | Mixed 80 | 16 | 12 | 309 | 0/0 | unclear | 3 | no
Shankar (2007)168 Asia Pharm. Fund Multicenter | South Asians, heterogeneous 10- year CHD risk estimates | Simvastatin 10 | 114 | Simvastatin 10 | 116 | 12 | 127 | 0/0 | unclear | 2 | yes
Stein (2008)148 International Pharm. fund | HC, Participants with documented statin associated muscle related side effects | Fluvastatin 80 | 64 | Fluvastatin 80 | 69 | 12 | 174 | 0/0 | Adequate | 5 | yes
Barrios (2005)112 International Pharm. fund | CHD or risk equivalent | Simvastatin 20 | 221 | Atorvastatin 20 | 214 | 6 | 124 | 0/0 | unclear | 3 | no
Cruz- Fernandez (2005)115 International Pharm. Fund Multicenter | Participants with CAD on low dose atorvastatin | Atorvastatin 10–20 | 220 | Atorvastatin 10–20 | 230 | 6 | 122 | 0/0 | unclear | 4 | no
Brohet (2005)116 Europe Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 208 | Simvastatin 10–20 | 210 | 6 | 123 | 0/0 | unclear | 5 | no
Ballantyne (2007)142 Europe Pharm. Fund Multicenter | CHD and risk equivalent | Rosuvastatin 40 | 238 | Rosuvastatin 40 | 230 | 6 | 190 | 0/0 | unclear | 1 | no
Chenot (2007)146 Europe Single centre | Tertiary care patients with acute MI | Simvastatin 40 | 20 | Simvastatin 40 | 20 | 1 | 146 | 0/0 | unclear | 1 | yes
Farnier (2005)114 International Pharm. Fund Multicenter | Participants with CAD on low dose simvastatin | Simvastatin 10–20 | 181 | Simvastatin 10–20 | 191 | 6 | 123 | 0/0 | unclear | 5 | no
Leiter (2008)159 North America Pharm. Fund Multicenter | Participants with or without prior lipid lowering therapy with 10-year CHD risk > 20% | Atorvastatin 40 | 281 | Atorvastatin 80 | 283 | 6 | 89 | 0/0 | Adequate | 5 | No
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | 0/0 | Adequate | 5 | Yes
Relative probability of participants experiencing rhabdomyolysis (investigator defined): all statins, lower versus higher doses, all clinical populations
Feldman (2004)47 North America Pharm. Fund Multicenter | Participants with CHD or risk equivalent | Simvastatin 10–20 | 360 | Simvastatin 40 | 253 | 23 | 169 | 0/0 | unclear | 2 | no
Dobs (2003)169 Pharm. Fund Multicenter | Participants of mixed 10 year CHD risk, with primary hyperlipidemia (LDL-c >=130 mg/dL) not controlled on simvastatin 20 mg/day | Simvastatin 20 | 66 | Simvastatin 40 | 34 | 4 | 169 | 0/0 | Adequate | 5 | Yes

## Included Evidence for Fibrate plus Statin Therapy Compared With Statin Monotherapy

Table F-9

Longer-term outcomes (clinical outcomes, serious adverse events and cancer) using fibrate plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Fibrate (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Trial Baseline LDL-c (mg/dL) | Combo/mono: number of participants with events Odds ratio (95% CI) | AAC | Jadad Score | ITTA
All-cause Mortality, all trials
Durrington (2004)125 4522IL/0036 Europe Pharm. Fund Multicentre | Participants with combined HC, HbA1c <10%, and T2DM | Rosuvastatin 5–10 | Fenofibrate 200 | 113 | Rosuvastatin 40 | 53 | 18 | 149 | 1/1 0.43 (0.02, 8.54) | unclear | 2 | No
Napoli (1997)188 Europe Single centre | FHC type IIb or FHCL, no vascular disease or DM | Pravastatin 20 | Gemfibrozil 1200 | 14 | Pravastatin 20 | 13 | 48–92 | NR | 0/0 | unclear | 1 | No
Wiklund (1993)134 Europe Pharm. Fund Multicentre | No specific risk reported | Pravastatin 40 | Gemfibrozil 1200 | 75 | Pravastatin 40 | 71 | 12 | 228 | 0/1 0.13 (0.00, 6.46) | unclear | 2 | No
Fatal myocardial infarction
Derosa (2004)123 Europe | Participants with combined HC, T2DM and CHD | Fluvastatin 80 | Fenofibrate 200 | 25 | Fluvastatin 80 | 23 | 52 | 189 | 0/0 | unclear | 3 | Yes
Wiklund (1993)134 Europe Pharm. Fund Multicentre | No specific risk reported | Pravastatin 40 | Gemfibrozil 1200 | 75 | Pravastatin 40 | 71 | 12 | 228 | 0/1 0.13 (0.00, 6.46) | unclear | 2 | No
Non-fatal myocardial infarction
Derosa (2004)123 Europe | Participants with combined HC, T2DM and CHD | Fluvastatin 80 | Fenofibrate 200 | 25 | Fluvastatin 80 | 23 | 52 | 189 | 0/0 | unclear | 3 | Yes
Any myocardial infarction
Derosa (2004)123 Europe | Participants with combined HC, T2DM and CHD | Fluvastatin 80 | Fenofibrate 200 | 25 | Fluvastatin 80 | 23 | 52 | 189 | 0/0 | unclear | 3 | Yes
Acute coronary syndrome
Derosa (2004)123 Europe | Participants with combined HC, T2DM and CHD | Fluvastatin 80 | Fenofibrate 200 | 25 | Fluvastatin 80 | 23 | 52 | 189 | 0/0 | unclear | 3 | Yes
Serious adverse event(s)
Derosa (2004)123 Europe | Participants with combined HC, T2DM and CHD | Fluvastatin 80 | Fenofibrate 200 | 25 | Fluvastatin 80 | 23 | 52 | 189 | 0/0 | unclear | 3 | Yes
Grundy (2005)120 SAFARI North America Multicentre | Combined HC 71% with MetS | Simvastatin 20 | Fenofibrate 160 | 403 | Simvastatin 20 | 201 | 12 | 163 | 12/5 1.2 (0.42,3.46) | yes | 2 | No

Table F-10

Surrogate outcome – Achieving ATP-III target LDL-c using fibrate plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Fibrate Max Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Trial Baseline LDL-c (mg/dL) | Combo/mono: number of participants with events Odds ratio (95% CI) | AAC | Jadad Score | ITTA
Athyros (2002)161 | Participants with combined HC, HbA1c <8.5%, T2DM and without CAD | Atorvastatin 20 | Fenofibrate 200 | 40 | Atorvastatin 20 | 40 | 24 | 162 | 39/32 9.75 (1.16, 82.11) | unclear | 1 | yes
Durrington (2004)125 | Participants with combined HC, HbA1c <10%, and T2DM | Rosuvastatin 5–10 | Fenofibrate 200 | 113 | Rosuvastatin 40 | 50 | 18 | 149 | 85/43 0.49 (0.20, 1.22) | unclear | 2 | No

Table F-11

Surrogate outcome, LDL-c using fibrate plus statin therapy compared with statin monotherapy

Low density lipoprotein cholesterol
Trial | Population | Combination Statin Dose (mg/day) | Fibrate (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Mean Baseline LDL-c (mg/dL) | Combo- mono: mean difference (95% CI) | AAC | Jadad Score | ITTA
Combination – monotherapy: difference in mean percentage change from baseline
Durrington (2004)125 4522IL/0036 Europe Pharm. Fund Multicenter | Participants with combined HC, HbA1c <10%, and T2DM | Rosuvastatin 10 | Fenofibrate 200 | 53 | Rosuvastatin 40 | 51 | 18 | 149 | 4.50 (−4.10, 13.1) | unclear | 2 | No
Muhlestein (2006)145 DIACOR study North America Pharm. Fund Single center | Participants with mixed dylipidemia, HbA1c <9%, T2DM and without CAD | Simvastatin 20 | Fenofibrate 160 | 100 | Simvastatin 20 | 100 | 12 | 278 | 5.00 (−1.47, 11.5) | unclear | 2 | Yes
Grundy (2005)120 SAFARI North America Multicenter | Combined HC 71% with MetS | Simvastatin 20 | Fenofibrate 160 | 399 | Simvastatin 20 | 201 | 12 | 163 | −5.40 (−8.39, −2.4) | yes | 2 | No

Table F-12

Surrogate outcome – HDL-c using fibrate plus statin therapy compared with statin monotherapy

High density lipoprotein cholesterol
Trial | Population | Combination Statin Dose (mg/day) | Fibrate (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow-up (wk) | Mean Baseline LDL-c (mg/dL) | Combo-mono: mean difference (95% CI) | AAC | Jadad Score | ITTA
Combination – monotherapy: difference in mean percentage change from baseline
Durrington (2004)125 4522IL/0036 Europe Pharm. Fund Multicenter | Participants with combined HC, HbA1c <10%, and T2DM | Rosuvastatin 5–10 | Fenofibrate 200 | 113 | Rosuvastatin 40 | 51 | 18 | 149 | 4.81 (−0.56, 10.18) | unclear | 2 | No
Muhlestein (2006)145 DIACOR study North America Pharm. Fund Single center | Participants with mixed dylipidemia, HbA1c <9%, T2DM and without CAD | Simvastatin 20 | Fenofibrate 160 | 100 | Simvastatin 20 | 100 | 12 | 278 | 5.60 (−0.19, 11.39) | unclear | 2 | Yes
Grundy (2005)120 SAFARI North America Multicenter | Combined HC 71% with MetS | Simvastatin 20 | Fenofibrate 160 | 399 | Simvastatin 20 | 201 | 12 | 163 | 8.80 (5.96, 11.64) | yes | 2 | No

Table F-13

Surrogate outcome – TC:HDL-c ratio using fibrate plus statin therapy compared with statin monotherapy

Total cholesterol : High density lipoprotein cholesterol
Trial | Population | Combination Statin Dose (mg/day) | Fibrate (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow-up (wk) | Mean Baseline LDL-c (mg/dL) | Combo-mono: mean difference (95% CI) | AAC | Jadad Score | ITTA
Combination – monotherapy: difference in mean percentage change from baseline
Durrington (2004)125 4522IL/0036 Europe Pharm. Fund Multicenter | Participants with combined HC, HbA1c <10%, and T2DM | Rosuvastatin 10 | Fenofibrate 200 | 53 | Rosuvastatin 40 | 51 | 18 | 149 | −2.70 (−10.46, 5.06) | unclear | 2 | No

Table F-14

Surrogate outcome – Non-HDL-c using fibrate plus statin therapy compared with statin monotherapy

Non-High density lipoprotein cholesterol
Trial | Population | Combination Statin Dose (mg/day) | Fibrate (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow-up (wk) | Mean Baseline LDL-c (mg/dL) | Combo-mono: mean difference (95% CI) | AAC | Jadad Score | ITTA
Combination – monotherapy: difference in mean percentage change from baseline
Muhlestein (2006)145 DIACOR study North America Pharm. Fund Single center | Participants with mixed dylipidemia, HbA1c <9%, T2DM and without CAD | Simvastatin 20 | Fenofibrate 160 | 100 | Simvastatin 20 | 100 | 12 | 278 | 1.80 (−3.01, 6.61) | unclear | 2 | Yes

Table F-15

Surrogate outcome – TG using fibrate plus statin therapy compared with statin monotherapy

Tryglicerides
Trial | Population | Combination Statin Dose (mg/day) | Fibrate (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow-up (wk) | Mean Baseline LDL-c (mg/dL) | Combo-mono: mean difference (95% CI) | AAC | Jadad Score | ITTA
Combination – monotherapy: difference in mean percentage change from baseline
Durrington (2004)125 4522IL/0036 Europe Pharm. Fund Multicenter | Participants with combined HC, HbA1c <10%, and T2DM | Rosuvastatin 10 | Fenofibrate 200 | 113 | Rosuvastatin 40 | 51 | 18 | 149 | −13.57 (−24.16, −2.98) | unclear | 2 | No

Table F-16

Adverse events and adherence to treatment using fibrate plus statin compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Fibrates Max Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow-up (wk) | Trial Baseline LDL-c (mg/dL) | Combo/mono: number of participants with events Odds ratio (95% CI) | AAC | Jadad Score | ITTA
Relative probability of participants experiencing an adverse event
Derosa (2004)123 Europe | Participants with combined HC, T2DM and CHD | Fluvastatin 80 | Fenofibrate 200 | 25 | Fluvastatin 80 | 23 | 52 | 189 | 3/2 1.43 (0.22, 9.44) | unclear | 3 | yes
Durrington (2004)125 4522IL/0036 Europe Pharm. Fund Multicenter | Participants with combined HC, HbA1c <10%, and T2DM | Rosuvastatin 5–10 | Fenofibrate 200 | 115 | Rosuvastatin 40 | 53 | 18 | 149 | 24/14 0.73 (0.34, 1.57) | unclear | 2 | no
Wiklund (1993)134 Europe Pharm. Fund Multicenter | No particular risk described | Pravastatin 40 | Gemfibrozil 1200 | 75 | Pravastatin 40 | 71 | 12 | 228 | 31/16 2.42 (1.18, 4.99) | unclear | 2 | no
Relative probability of participants withdrawing from treatment due to an adverse event
Athyros (2001)50 Europe Single centre | Participants with familial combined HC | Simvastatin 20 | Gemfibrozil 1200 | 136 | Atorvastatin 20 | 134 | 52 | | 7/1 7.22 (0.88, 59.48) | unclear | 3 | no
Athyros (2002)161 Europe | Participants with combined HC, HbA1c <8.5%, T2DM and without CAD | Atorvastatin 20 | Fenofibrate 200 | 40 | Atorvastatin 20 | 40 | 24 | 162 | 0/0 | unclear | 1 | yes
Durrington (2004)125 4522IL/0036 Europe Pharm. Fund Multicenter | Participants with combined HC, HbA1c <10%, and T2DM | Rosuvastatin 5–10 | Fenofibrate 200 | 115 | Rosuvastatin 40 | 53 | 18 | 149 | 2/3 0.29 (0.05, 1.82) | unclear | 2 | no
Grundy (2005)120 SAFARI North America Multicenter | Combined HC, 71% with MetS | Simvastatin 20 | Fenofibrate 160 | 403 | Simvastatin 20 | 202 | 12 | 163 | 13/5 1.31 (0.46, 3.74) | yes | 2 | no
Wiklund (1993)134 Europe Pharm. Fund Multicenter | No particular risk described | Pravastatin 40 | Gemfibrozil 1200 | 75 | Pravastatin 40 | 71 | 12 | 228 | 8/2 4.12 (0.84, 20.11) | unclear | 2 | no
Relative probability of participants experiencing elevated serum AST and/or ALT > 3 times ULN and/or hepatitis
Athyros (2005)160 | Participants with MetS (NCEP ATP III), without overt DM or CVD | Atorvastatin 20 | Fenofibrate 200 | 100 | Atorvastatin 20 | 100 | 54 | 151 | 0/1 0.33 (0.01, 8.20) | yes | 2 | yes
Athyros (2001)50 Europe Single centre | Participants with familial combined HC | Mixed 20 | Gemfibrozil 1200 | 262 | Atorvastatin 20 | 131 | 52 | | 4/0 4.58 (0.24, 85.68) | unclear | 3 | no
Athyros (2002)161 Europe | Participants with combined HC, HbA1c <8.5%, T2DM and without CAD | Atorvastatin 20 | Fenofibrate 200 | 40 | Atorvastatin 20 | 40 | 24 | 162 | 0/0 | unclear | 1 | yes
Durrington (2004)125 | Participants with combined HC, HbA1c <10%, and T2DM | Rosuvastatin 5–10 | Fenofibrate 200 | 115 | Rosuvastatin 40 | 53 | 18 | 149 | 6/0 6.35 (0.35, 114.85) | unclear | 2 | no
Relative probability of participants experiencing myalgia
Athyros (2001)50 | Participants with familial combined HC | Mixed 20 | Gemfibrozil 1200 | 262 | Atorvastatin 20 | 131 | 52 | | 2/0 2.52 (0.12, 52.95) | unclear | 3 | no
Napoli (1997)188 | Participants with familial combined HC (type IIb) | Pravastatin 20 | Gemfibrozil 1200 | 14 | Pravastatin 20 | 13 | 52–104 | | 1/1 0.92 (0.05, 16.46) | unclear | 1 | no
Durrington (2004)125 | Participants with combined HC, HbA1c <10%, and T2DM | Rosuvastatin 5–10 | Fenofibrate 200 | 115 | Rosuvastatin 40 | 53 | 18 | 149 | 3/1 1.39 (0.14, 13.71) | unclear | 2 | no
Grundy (2005)120 | Combined HC 71% with MetSyn | Simvastatin 20 | Fenofibrate 160 | 403 | Simvastatin 20 | 202 | 12 | 163 | 8/5 0.80 (0.26, 2.47) | yes | 2 | no
Wiklund (1993)134 | No particular risk described | Pravastatin 40 | Gemfibrozil 1200 | 75 | Pravastatin 40 | 71 | 12 | 228 | 7/1 7.21 (0.86, 60.14) | unclear | 2 | no
Shah (2007_1)195 | Participants with acute coronary syndrome who underwent PTCA procedure, regardless of DM | Atorvastatin 10 | Fenofibrate 200 | 25 | Atorvastatin 20 | 25 | 12 | 95 | 0/0 | unclear | 1 | no
Shah (2007_2)195 | Participants with acute coronary syndrome who underwent PTCA procedure, regardless of DM | Simvastatin 20 | Fenofibrate 200 | 25 | Simvastatin 40 | 25 | 12 | 95 | 0/2 0.18 (0.01, 4.04) | unclear | 1 | no
Relative probability of participants experiencing CPK greater than 10 times the upper limit of normal
Athyros (2002)161 | Participants with combined HC, HbA1c <8.5%, T2DM and without CAD | Atorvastatin 20 | Fenofibrate 200 | 40 | Atorvastatin 20 | 40 | 24 | 162 | 0/0 | unclear | 1 | yes
Durrington (2004)125 | Participants with combined HC, HbA1c <10%, and T2DM | Rosuvastatin 5–10 | Fenofibrate 200 | 115 | Rosuvastatin 40 | 53 | 18 | 149 | 0/0 | unclear | 2 | no
Grundy (2005)120 | Combined HC, 71% with MetS | Simvastatin 20 | Fenofibrate 160 | 403 | Simvastatin 20 | 202 | 12 | 163 | 1/0 4.49 (0.07, 286.36) | yes | 2 | no
Muhlestein (2006)145 | Participants with mixed dyslipidemia, HbA1c <9%, T2DM and without CAD | Simvastatin 20 | Fenofibrate 160 | 100 | Simvastatin 20 | 100 | 12 | 278 | 0/0 | unclear | 2 | yes
Wiklund (1993)134 | No particular risk described | Pravastatin 40 | Gemfibrozil 1200 | 75 | Pravastatin 40 | 71 | 12 | 228 | 0/0 | unclear | 2 | no
Relative probability of participants experiencing rhabdomyolysis (investigator defined)
Grundy (2005)120 | Combined HC, 71% with MetS | Simvastatin 20 | Fenofibrate 160 | 403 | Simvastatin 20 | 202 | 12 | 163 | 0/0 | yes | 2 | no
Wiklund (1993)134 | No particular risk described | Pravastatin 40 | Gemfibrozil 1200 | 75 | Pravastatin 40 | 71 | 12 | 228 | 0/0 | unclear | 2 | no
Muhlestein (2006)145 | Participants with mixed dyslipidemia, HbA1c <9%, T2DM and without CAD | Simvastatin 20 | Fenofibrate 160 | 100 | Simvastatin 20 | 100 | 12 | 278 | 0/0 | unclear | 2 | yes

## Included Evidence For Niacin Plus Statin Therapy Compared With Statin Monotherapy

Table F-17

Longer-term outcomes (clinical outcomes, serious adverse events and cancer) using niacin plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Niacin | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow up (wk) | Trial Baseline LDL-c (mg/dL) | Difference (95% CI) [combo-mono] | AAC | Jadad Score | ITTA
All-cause mortality – patients requiring intensive lipid lowering therapy
Taylor (2004)196 ARBITER North America Single centre | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 130 mg/dL and HDL-C < 45 mg/dL | Mixed >20 | Ext Rls | 78 | Mixed >20 | 71 | 52 | 89 | 2/1 1.84 (0.16, 20.76) | yes | 5 | No
All-cause mortality
Taylor (2004)196 ARBITER North America Single centre | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 130 mg/dL and HDL-C < 45 mg/dL | Mixed >20 | Ext Rls | 78 | Mixed >20 | 71 | 52 | 89 | 2/1 1.84 (0.16, 20.76) | yes | 5 | No
Kos Pharm (MA-06)105 MA-06 North America Multicenter | Participants with hyperlipidemi a type IIa or IIb, Statin naïve | Lovastatin 40 | Ext Rls | 114 | Lovastatin 40 | 61 | 28 | 189 | 1/1 0.53 (0.03, 8.64) | yes | 5 | No
Kos Pharm (MA-14)104 MA-14 North America Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) ; Statin naïve. | Lovastatin 10 | Ext Rls | 100 | Lovastatin 40 | 33 | 20 | 198 | 0/0 | yes | 4 | No
Stein (1996)170 North America Pharm. Fund Multicenter | Participants with elevated low-density lipoprotein cholesterol, high triglycerides, and low high-density lipoprolein cholesteroL | Simvastatin 10 | Imm Rls | 60 | Simvastatin 10 | 60 | 17 | 176 | 0/0 | unclear | 2 | No
Ballantyne (2008_a)150 North America, South America, Europe Pharm. Fund Multicenter | Participants with increased ATP III risk adjusted non-HDL-c but on target LDL-c on run-in simvastatin 20 mg/day | Simvastatin 20 | Ext Rls 1000–2000 | 187 | Simvastatin 20 | 114 | 24 | | 0/0 | unclear | 3 | No
Ballantyne (2008_b)171 North America, South America, Pharm. Fund Multicenter | Participants with elevated non-HDL-c level desipte run-in simvastatin 40 mg/day | Simvastatin 40 | Ext Rls 1000–2000 | 216 | Simvastatin 80 | 119 | 24 | | 0/0 | adequate | 3 | No
All-cause mortality – Adequate Allocation Concealment
Taylor (2004)196 ARBITER North America Single centre | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 130 mg/dL and HDL-C < 45 mg/dL | Mixed >20 | Ext Rls | 78 | Mixed >20 | 71 | 52 | 89 | 2/1 1.84 (0.16, 20.76) | yes | 5 | No
Kos Pharm (MA-06)105 MA-06 North America Multicenter | Participants with hyperlipidemia type IIa or IIb, Statin naïve | Lovastatin 40 | Ext Rls | 114 | Lovastatin 40 | 61 | 28 | 189 | 1/1 0.53 (0.03, 8.64) | yes | 5 | No
Kos Pharm (MA-14)104 MA-14 North America Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) ; Statin naïve. | Lovastatin 10 | Ext Rls | 100 | Lovastatin 40 | 33 | 20 | 198 | 0/0 | yes | 4 | No
Ballantyne (2008_b)171 North America, South America, Pharm. Fund Multicenter | Participants with elevated non-HDL-c level desipte run-in simvastatin 40 mg/day | Simvastatin 40 | Ext Rls | 216 | Simvastatin 80 | 119 | 24 | | 0/0 | adequate | 3 | No
All-cause mortality – patients with vascular disease
Taylor (2004)196 ARBITER North America Single centre | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 130 mg/dL and HDL-C < 45 mg/dL | Mixed >20 | Ext Rls | 78 | Mixed >20 | 71 | 52 | 89 | 2/1 1.84 (0.16, 20.76) | yes | 5 | No
Vascular death – patients requiring intensive lipid lowering therapy
Kuvin (2006)197 North America Pharm. Fund Single center | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 100 mg/dL | Mixed | Ext Rls | 27 | Mixed | 27 | 12 | 79 | 0/0 | unclear | 1 | No
Vascular death
Hunninghake (2003)128 North America Pharm. Fund Multicenter | Participants with type IIA hyperlipidemia or type IIB hyperlipidemia | Lovastatin 40 | Ext Rls | 114 | Lovastatin 40 | 61 | 28 | 189 | 1/1 0.53 (0.03, 8.64) | unclear | 4 | Yes
Kuvin (2006)197 North America Pharm. Fund Single center | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 100 mg/dL | Mixed | Ext Rls | 27 | Mixed | 27 | 12 | 79 | 0/0 | unclear | 1 | No
Vascular death – patients with vascular disease
Kuvin (2006)197 North America Pharm. Fund Single center | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 100 mg/dL | Mixed | Ext Rls | 27 | Mixed | 27 | 12 | 79 | 0/0 | unclear | 1 | No
Fatal myocardial infarction
Kos Pharm (MA-06)105 MA-06 North America Multicenter | Participants with hyperlipidemia type IIa or IIb, Statin naïve | Lovastatin 40 | Ext Rls | 114 | Lovastatin 40 | 61 | 28 | 189 | 1/0 1.63 (0.07, 40.51) | yes | 5 | No
Kuvin (2006)197 North America Pharm. Fund Single center | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 100 mg/dL | Mixed | Ext Rls | 27 | Mixed | 27 | 12 | 79 | 0/0 | unclear | 1 | No
Any stroke
Taylor (2004)196 ARBITER North America Single centre | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 130 mg/dL and HDL-C < 45 mg/dL | Mixed >20 | Ext Rls | 78 | Mixed >20 | 71 | 52 | 89 | 0/1 0.12 (0.00, 6.21) | yes | 5 | No
Acute coronary syndrome
Taylor (2004)196 ARBITER North America Single centre | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 130 mg/dL and HDL-C < 45 mg/dL | Mixed >20 | Ext Rls | 78 | Mixed >20 | 71 | 52 | 89 | 2/2 0.91 (0.12, 6.62) | yes | 5 | No
Percutaneous coronary intervention
Taylor (2004)196 ARBITER North America Single centre | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 130 mg/dL and HDL-C < 45 mg/dL | Mixed >20 | Ext Rls | 78 | Mixed >20 | 71 | 52 | 89 | 4/1 3.78 (0.41, 34.68) | yes | 5 | No
Serious adverse events
Kos Pharm (MA-06)105 MA-06 North America Multicenter | Participants with hyperlipidemia type IIa or IIb, Statin naïve | Lovastatin 20–40 | Ext Rls | 114 | Lovastatin 40 | 61 | 28 | 189 | 5/2 1.35 (0.25, 7.19) | yes | 5 | No
Kos Pharm (MA-14)104 MA-14 North America Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) ; Statin naïve. | Lovastatin 10–40 | Ext Rls | 100 | Lovastatin 40 | 33 | 20 | 198 | 5/1 1.68 (0.19, 14.96) | yes | 4 | No
Stein (1996)170 North America Pharm. Fund Multicentre | Participants with elevated low-density lipoprotein cholesterol, high triglycerides, and low high-density lipoprolein cholesteroL | Simvastatin 10 | Imm Rls | 60 | Simvastatin 10 | 60 | 17 | 176 | 1/0 3.05 (0.12, 76.39) | unclear | 2 | No
Ballantyne (2008_a)150 North America, South America, Europe Pharm. Fund Multicenter | Participants with increased ATP III risk adjusted non-HDL-c but on target LDL-c on run-in simvastatin 20 mg/day | Simvastatin 20 | Ext Rls | 187 | Simvastatin 20 | 114 | 24 | | 1/0 1.84 (0.07, 45.60) | unclear | 3 | No
Ballantyne (2008_b)171 North America, South America, Pharm. Fund Multicenter | Participants with elevated non-HDL-c level desipte run-in simvastatin 40 mg/day | Simvastatin 40 | Ext Rls | 216 | Simvastatin 80 | 119 | 24 | 104 | 0/1 0.18 (0.01, 4.51) | adequate | 3 | No
Cancer
Kos Pharm (MA-06)105 MA-06 North America Multicenter | Participants with hyperlipidemia type IIa or IIb, Statin naïve | Lovastatin 20–40 | Ext Rls | 114 | Lovastatin 40 | 61 | 28 | 189 | 0/2 0.10 (0.00, 2.2) | yes | 5 | No

Table F-18

Surrogate outcome – Achieving ATP-III target LDL-c using niacin plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Niacin Max Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow up (wk) | Trial Baseline LDL-c (mg/dL) | Number of Events Odds Ratio (95% CI) [combo/mono] | AAC | Jadad Score | ITTA
Relative probability of attaining ATPIII LDL-c target - Participants requiring intensive lipid lowering therapy
Bays (2003)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels and vascular disease | Lovastatin 40 | Ext Rls 2000 | 32 | Mixed 40 | 34 | 16 | 192 | 21/19 1.51 (0.56, 4.08) | unclear | 1 | no
Relative probability of attaining ATPIII LDL-c target
Bays (2003_1)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels | Lovastatin 40 | Ext Rls 2000 | 53 | Simvastatin 40 | 57 | 16 | 192 | 40/38 1.54 (0.67, 3.54) | unclear | 1 | no
Bays (2003_2)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels | Lovastatin 40 | Ext Rls 2000 | 52 | Atorvastatin 40 | 60 | 16 | 192 | 38/50 0.54 (0.22, 1.4) | unclear | 1 | no
Relative probability of attaining ATPIII LDL-c target - Participants with vascular disease
Bays (2003)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels and vascular disease | Lovastatin 40 | Ext Rls 2000 | 32 | Mixed 40 | 34 | 16 | 192 | 21/19 1.51 (0.56, 4.08) | unclear | 1 | No

Table F-19

Surrogate outcome – LDL-c using niacin plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Niacin Max Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow up (wk) | Trial Baseline LDL-c (mg/dL) | Number of Events Odds Ratio (95% CI) [combo/mono] | AAC | Jadad Score | ITTA
Difference in mean percentage change from baseline - Rosuvastatin Lower dose statin in combination versus higher dose monotherapy
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 10 | Ext Rls | 78 | Rosuvastatin 40 | 46 | 24 | 145 | 12.00 (2.26, 21.74) | unclear | 2 | No
Difference in mean percentage change from baseline - Participants requiring intensive lipid lowering therapy
Moore (2007)162 North America, Pharm. Fund Single icenter | Participants with increased ATP III risk adjusted non-HDL-c but on target LDL-c on run-in simvastatin 20 mg/day | Atorvastatin 20 | Ext Rls | 41 | Atorvastatin 30 | 42 | 48 | 154 | 0 (−6.51, 6.51) | unclear | 2 | Yes
Difference in mean percentage change from baseline
Kos Pharm (MA-06)105 MA-06 North America Multicenter | Participants with hyperlipidem ia type IIa or IIb, Statin naïve | Lovastatin 40 | Ext Rls | 42 | Lovastatin 40 | 53 | 28 | 189 | −9.70 (−14.64, −4.76) | yes | 5 | No
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 10–40 | Ext Rls | 149 | Rosuvastatin 40 | 46 | 24 | 145 | 9.00 (−2.45, 20.45) | unclear | 2 | No
Insull (2004)182 North America Pharm. Fund Multicenter | Participants with type IIa or IIb primary hyperlipidemia, statin naïve | Lovastatin 40 | Ext Rls | 32 | Lovastatin 40 | 33 | 20 | 198 | −22.20 (−32.09, −12.31) | unclear | 2 | No
Kos Pharm (MA-14)104 MA-14 North America Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) ; Statin naïve. | Lovastatin 40 | Ext Rls | 23 | Lovastatin 40 | 29 | 20 | 198 | −22.20 (−31.64, −12.76) | yes | 4 | No
McKenney (2007_2)139 COMPELL study North America Pharm. Fund Multicenter | HC, heterogeneous 10-year CHD risk estimates | Atorvastatin 40 | Ext Rls | 60 | Rosuvastatin 40 | 73 | 12 | 197 | −3.00 (−8.30, 2.30) | unclear | 2 | No
Vacek (1995)184 North America Pharm. Fund Single centre | Cross-over trial; Participants with LDL >180 | Lovastatin 20 | Slow release | 25 | Lovastatin 20 | 25 | 12 | 204 | −25.00 (−40.60, −9.40) | unclear | 2 | No
Moore (2007)162 North America, Pharm. Fund Single center | Participants with increased ATP III risk adjusted non-HDL-c but on target LDL-c on run-in simvastatin 20 mg/day | Atorvastatin 20 | Ext Rls | 41 | Atorvastatin 30 | 42 | 48 | 154 | 0 (−6.51, 6.51) | unclear | 2 | Yes

Table F-20

Surrogate outcome – HDL-c using niacin plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Niacin Max Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow up (wk) | Trial Baseline LDL-c (mg/dL) | Number of Events Odds Ratio (95% CI) [combo/mono] | AAC | Jadad Score | ITTA
Difference in mean percentage change from baseline – Participants requiring intensive lipid lowering
Moore (2007)162 North America, Pharm. Fund Single center | Participants with increased ATP III risk adjusted non-HDL-c but on target LDL-c on run-in simvastatin 20 mg/day | Atorvastatin 20 | Ext Rls | 41 | Atorvastatin 30 | 42 | 48 | 154 | 13.00 (6.01, 19.99) | unclear | 2 | Yes
Difference in mean percentage change from baseline
Kos Pharm (MA-06)105 MA-06 North America Multicenter | Participants with hyperlipidemia type IIa or IIb, Statin naïve | Lovastatin 40 | Ext Rls | 42 | Lovastatin 40 | 53 | 28 | 189 | 24.00 (17.50, 30.50) | yes | 5 | no
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 40 | Ext Rls | 71 | Rosuvastatin 40 | 46 | 24 | 145 | 6.00 (−0.79, 12.79) | unclear | 2 | no
Insull (2004)182 North America Pharm. Fund Multicenter | Participants with type IIa or IIb primary hyperlipidemia, statin naïve | Lovastatin 10–40 | Ext Rls | 100 | Lovastatin 40 | 33 | 20 | 198 | 24.00 (14.86, 33.14) | unclear | 2 | no
Kos Pharm (MA-14)104 MA-14 North America Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) ; Statin naïve. | Lovastatin 10–40 | Ext Rls | 77 | Lovastatin 40 | 29 | 20 | 198 | 24.00 (15.36, 32.64) | yes | 4 | no
McKenney (2007_2)139 COMPELL study North America Pharm. Fund Multicenter | HC, heterogeneou s 10-year CHD risk estimates | Mixed 20–40 | Ext Rls | 125 | Rosuvastatin 40 | 73 | 12 | 197 | 16.00 (11.43, 20.57) | unclear | 2 | no
Moore (2007)162 North America, Pharm. Fund Single center | Participants with increased ATP III risk adjusted non-HDL-c but on target LDL-c on run-in simvastatin 20 mg/day | Atorvastatin 20 | Ext Rls | 41 | Atorvastatin 30 | 42 | 48 | 154 | 13.00 (6.01, 19.99) | unclear | 2 | Yes
Difference in mean percentage change from baseline - Rosuvastatin Lower dose statin in combination versus higher dose monotherapy
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 10 | Ext Rls | 71 | Rosuvastatin 40 | 46 | 24 | 145 | 13.00 (6.10, 19.90) | unclear | 2 | no

Table F-21

Surrogate outcome – TC:HDL-c ratio using niacin plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Niacin Max Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow up (wk) | Trial Baseline LDL-c (mg/dL) | Difference (95% CI) [combo-mono] | AAC | Jadad Score | ITTA
Difference in mean percentage change in TC-HDL-c ratio
McKenney (2007_2)139 | HC, heterogeneous 10-year CHD risk estimates | Mixed 20–40 | Ext Rls 2000 | 125 | Rosuvastatin 40 | 73 | 12 | 197 | −6.00 (−9.60, −2.40) | unclear | 2 | no

Table F-22

Carotid intima-media thickness (CIMT) using niacin plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Niacin Max Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow up (wk) | Trial Baseline LDL-c (mg/dL) | Difference (95% CI) [combo-mono] | AAC | Jadad Score | ITTA
Taylor (2004)196 ARBITER North America Single centre | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 130 mg/dL and HDL-C < 45 mg/dL | Mixed >20 | Ext Rls 1000 | 71 | Mixed >20 | 78 | 52 | 89 | −0.03 (−0.06, 0.00) | yes | 5 | no

Table F-23

Adverse events and adherence to treatment using niacin plus statin compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Niacin Max Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow up (wk) | Trial Baseline LDL-c (mg/dL) | Number of Events Odds Ratio (95% CI) [combo/mono] | AAC | Jadad Score | ITTA
Relative probability of participants adhering to treatment
Taylor (2004)196 ARBITER North America Single centre | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 130 mg/dL and HDL-C < 45 mg/dL | Mixed >20 | Ex Rls 1000 | 87 | Mixed >20 | 80 | 52 | 89 | 78/71 1.10 (0.41, 2.92) | yes | 5 | no
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 10–40 | Ex Rls 2000 | 152 | Rosuvastatin 40 | 46 | 24 | 145 | 71/31 0.42 (0.21, 0.85) | unclear | 2 | no
Insull (2004)182 North America Pharm. Fund Multicenter | Participants with type IIa or IIb primary hyperlipidemia, statin naïve | Lovastatin 10–40 | Ex Rel 2500 | 100 | Lovastatin 40 | 33 | 20 | 198 | 96/32 0.75 (0.08, 6.96) | unclear | 2 | no
Bays (2003_1)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels | Lovastatin 20–40 | Ex Rls 2000 | 78 | Simvastatin 10–40 | 76 | 16 | 192 | 73/73 0.60 (0.14, 2.60) | unclear | 1 | no
Bays (2003_2)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels | Lovastatin 20–40 | Ex Rls 2000 | 79 | Atorvastatin 10–40 | 82 | 16 | 192 | 77/79 1.46 (0.24, 8.99) | unclear | 1 | no
McKenney (2007_2)139 COMPELL study North America Pharm. Fund Multicenter | HC, heterogeneous 10-year CHD risk estimates | Mixed 20–40 | Ex Rls 2000 | 125 | Rosuvastatin 40 | 73 | 12 | 197 | 109/61 1.34 (0.60, 3.0) | unclear | 2 | no
Relative probability of participants adhering to treatment
Taylor (2004)196 ARBITER North America Single centre | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 130 mg/dL and HDL-C < 45 mg/dL | Mixed >20 | Ex Rls 1000 | 87 | Mixed >20 | 80 | 52 | 89 | 78/71 1.10 (0.41, 2.92) | yes | 5 | no
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 10–40 | Ex Rls 2000 | 152 | Rosuvastatin 40 | 46 | 24 | 145 | 71/31 0.42 (0.21, 0.85) | unclear | 2 | no
Relative probability of participants adhering to treatment – Rosuvastatin - Lower dose statin in combination versus higher dose monotherapy
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 10 | Ex Rls 2000 | 80 | Rosuvastatin 40 | 46 | 24 | 145 | 36/31 0.42 (0.19, 0.84) | unclear | 2 | no
Relative probability of participants experiencing an adverse event
Kos Pharm (MA-06)105 MA-06 North America Multicenter | Participants with hyperlipidemia type IIa or IIb, Statin naïve | Lovastatin 20–40 | Ex Rls 2000 | 114 | Lovastatin 40 | 61 | 28 | 189 | 110/49 6.73 (2.07, 21.93) | yes | 5 | no
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 10–40 | Ex Rls 2000 | 152 | Rosuvastatin 40 | 46 | 24 | 145 | 129/34 1.98 (0.90, 4.38) | unclear | 2 | no
Insull (2004)182 North America Pharm. Fund Multicenter | Participants with type IIa or IIb primary hyperlipidemia, statin naïve | Lovastatin 10–40 | Ex Rls 2500 | 100 | Lovastatin 40 | 33 | 20 | 198 | 53/17 1.06 (0.48, 2.33) | unclear | 2 | no
Kos Pharm (MA-14)104 MA-14 North America Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia); Statin naïve. | Lovastatin 10–40 | Ex Rls 2500 | 100 | Lovastatin 40 | 33 | 20 | 198 | 88/24 2.75 (1.04, 7.29) | yes | 4 | no
Ballantyne (2008_a)150 North America, South America, Europe Pharm. Fund Multicenter | Participants with increased ATP III risk adjusted non-HDL-c but on target LDL-c on run-in simvastatin 20 mg/day | Simvastatin 20 | Ext Rls 1000–2000 | 187 | Simvastatin 20 | 114 | 24 | | 54/20 1.91 (1.07, 3.40) | unclear | 3 | No
Ballantyne (2008_b)171 North America, South America, Pharm. Fund Multicenter | Participants with elevated non-HDL-c level desipte run-in simvastatin 40 mg/day | Simvastatin 40 | Ext Rls 1000–2000 | 216 | Simvastatin 80 | 119 | 24 | 104 | 68/35 1.10 (0.68, 1.80) | adequate | 3 | No
Relative probability of participants experiencing an adverse event – 24 weeks or longer follow-up
Kos Pharm (MA-06)105 MA-06 North America Multicenter | Participants with hyperlipidemia type IIa or IIb, Statin naïve | Lovastatin 20–40 | Ex Rls 2000 | 114 | Lovastatin 40 | 61 | 28 | 189 | 110/49 6.73 (2.07, 21.93) | yes | 5 | no
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 10–40 | Ex Rls 2000 | 152 | Rosuvastatin 40 | 46 | 24 | 145 | 129/34 1.98 (0.90, 4.38) | unclear | 2 | no
Ballantyne (2008_a)150 North America, South America, Europe Pharm. Fund Multicenter | Participants with increased ATP III risk adjusted non-HDL-c but on target LDL-c on run-in simvastatin 20 mg/day | Simvastatin 20 | Ext Rls 1000–2000 | 187 | Simvastatin 20 | 114 | 24 | | 54/20 1.91 (1.07, 3.40) | unclear | 3 | No
Ballantyne (2008_b)171 North America, South America, Pharm. Fund Multicenter | Participants with elevated non-HDL-c level desipte run-in simvastatin 40 mg/day | Simvastatin 40 | Ext Rls 1000–2000 | 216 | Simvastatin 80 | 119 | 24 | 104 | 68/35 1.10 (0.68, 1.80) | adequate | 3 | No
Relative probability of participants experiencing an adverse event – Rosuvastatin - Lower dose statin in combination versus higher dose monotherapy
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 10 | Ex Rls 2000 | 78 | Rosuvastatin 40 | 46 | 24 | 145 | 66/34 1.94 (0.79, 4.78) | unclear | 2 | no
Relative probability of participants withdrawing from treatment due to an adverse event
Taylor (2004)196 ARBITER North America Single centre | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 130 mg/dL and HDL-C < 45 mg/dL | Mixed >20 | Ex Rls 1000 | 87 | Mixed >20 | 80 | 52 | 89 | 2/6 0.29 (0.06, 1.48) | yes | 5 | no
Hunninghake (2003)128 North America Pharm. Fund Multicenter | Participants with type IIA hyperlipidemia or type IIB hyperlipidemia | Lovastatin 20–40 | Ex Rls 2000 | 114 | Lovastatin 40 | 61 | 28 | 189 | 22/6 2.19 (0.84, 5.74) | unclear | 4 | yes
Kos Pharm (MA-06)105 MA-06 North America Multicenter | Participants with hyperlipidemia type IIa or IIb, Statin naïve | Lovastatin 20–40 | Ex Rls 2000 | 114 | Lovastatin 40 | 61 | 28 | 189 | 22/6 2.19 (0.84, 5.74) | yes | 5 | no
Insull (2004)182 North America Pharm. Fund Multicenter | Participants with type IIa or IIb primary hyperlipidemia, statin naïve | Lovastatin 10–40 | Ex Rls 2500 | 100 | Lovastatin 40 | 33 | 20 | 198 | 18/3 2.20 (0.60, 7.99) | unclear | 2 | no
Kos Pharm (MA-14)104 MA-14 North America Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia); Statin naïve. | Lovastatin 10–40 | Ex Rls 2500 | 100 | Lovastatin 40 | 33 | 20 | 198 | 18/3 2.20 (0.60, 7.99) | yes | 4 | no
O’Keefe (1995)189 North America Single centre | Adults with total cholesterol levels >180 mg/dL, HDL levels <40 mg/dL, and triglyceride levels >150 mg/dL | Pravastatin 20 | Imm Rls 3000 | 27 | Pravastatin 20 | 19 | 18 | 134 | 6/0 11.79 (0.62, 223.26) | unclear | 1 | no
Stein (1996)170 North America Pharm. Fund Multicenter | Participants with elevated low-density lipoprotein cholesterol, high triglycerides, and low high-density lipoprolein cholesteroL | Simvastatin 10 | Imm Rls 1500 | 60 | Simvastatin 10 | 60 | 17 | 176 | 9/3 3.35 (0.86, 13.07) | unclear | 2 | no
Bays (2003_1)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels | Lovastatin 20–40 | Ex Rls 2000 | 78 | Simvastatin 10–40 | 76 | 16 | 192 | 15/2 8.81 (1.94, 40.01) | unclear | 1 | no
Bays (2003_2)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels | Lovastatin 20–40 | Ex Rls 2000 | 79 | Atorvastatin 10–40 | 82 | 16 | 192 | 13/8 1.82 (0.71, 4.67) | unclear | 1 | no
Ballantyne (2008_a)150 North America, South America, Europe Pharm. Fund Multicenter | Participants with increased ATP III risk adjusted non-HDL-c but on target LDL-c on run-in simvastatin 20 mg/day | Simvastatin 20 | Ext Rls 1000–2000 | 187 | Simvastatin 20 | 114 | 24 | | 25/6 2.78 (1.10, 7.00) | unclear | 3 | No
Ballantyne (2008_b)171 North America, South America, Pharm. Fund Multicenter | Participants with elevated non-HDL-c level desipte run-in simvastatin 40 mg/day | Simvastatin 40 | Ext Rls 1000–2000 | 216 | Simvastatin 80 | 119 | 24 | 104 | 25/5 2.98 (1.11, 8.01) | adequate | 3 | No
Relative probability of participants experiencing Rhabdomyolysis
Kos Pharm (MA-06)105 MA-06 North America Multicenter | Participants with hyperlipidemia type IIa or IIb, Statin naïve | Lovastatin 20–40 | Ex Rls 2000 | 114 | Lovastatin 40 | 61 | 28 | 189 | 0/0 | yes | 5 | no
Kos Pharm (MA-14)104 MA-14 North America Multicenter | HC type IIa or IIb statin naive | Lovastatin 10–40 | Ex Rls 2500 | 100 | Lovastatin 40 | 33 | 20 | 198 | 0/0 | yes | 4 | no
Ballantyne (2008_a)150 North America, South America, Europe Pharm. Fund Multicenter | Participants with increased ATP III risk adjusted non-HDL-c but on target LDL-c on run-in simvastatin 20 mg/day | Simvastatin 20 | Ext Rls 1000–2000 | 187 | Simvastatin 20 | 114 | 24 | | 0/0 | unclear | 3 | No
Ballantyne (2008_b)171 North America, South America, Pharm. Fund Multicenter | Participants with elevated non-HDL-c level desipte run-in simvastatin 40 mg/day | Simvastatin 40 | Ext Rls 1000–2000 | 216 | Simvastatin 80 | 119 | 24 | 104 | 0/0 | adequate | 3 | No
Relative probability of participants experiencing elevated serum AST and/or ALT > 3 times ULN and/or hepatitis
Taylor (2004)196 ARBITER North America Single centre | Participants with coronary artery disease, and currently treated with a statin drug, with LDL-C < 130 mg/dL and HDL-C < 45 mg/dL | Mixed >20 | Ex Rls 1000 | 78 | Mixed >20 | 71 | 52 | 89 | 0/0 | yes | 5 | no
Hunninghake (2003)128 North America Pharm. Fund Multicenter | Participants with type IIA hyperlipidemia or type IIB hyperlipidemia | Lovastatin 20–40 | Ex Rls 2000 | 114 | Lovastatin 40 | 61 | 28 | 189 | 1/1 0.53 (0.03, 8.64) | unclear | 4 | yes
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 10–40 | Ex Rls 2000 | 152 | Rosuvastatin 40 | 46 | 24 | 145 | 0/0 | unclear | 2 | no
Insull (2004)182 North America Pharm. Fund Multicenter | Participants with type IIa or IIb primary hyperlipidemia, statin naïve | Lovastatin 10–40 | Ex Rls 2500 | 100 | Lovastatin 40 | 33 | 20 | 198 | 4/0 3.12 (0.16, 59.58) | unclear | 2 | no
Kos Pharm (MA-14)104 MA-14 North America Multicenter | HC type IIa or IIb statin naive | Lovastatin 10–40 | Ex Rls 2500 | 100 | Lovastatin 40 | 33 | 20 | 198 | 4/0 3.12 (0.16, 59.58) | yes | 4 | no
Stein (1996)170 North America Pharm. Fund Multicenter | Participants with elevated low-density lipoprotein cholesterol, high triglycerides, and low high-density lipoprolein cholesteroL | Simvastatin 10 | Imm Rls 1500 | 60 | Simvastatin 10 | 60 | 17 | 176 | 0/1 0.33 (0.01, 8.21) | unclear | 2 | no
Bays (2003_1)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels | Lovastatin 20–40 | Ex Rls 2000 | 78 | Simvastatin 10–40 | 76 | 16 | 192 | 0/0 | unclear | 1 | no
Bays (2003_2)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels | Lovastatin 20–40 | Ex Rls 2000 | 79 | Atorvastatin 10–40 | 82 | 16 | 192 | 0/0 | unclear | 1 | no
Ballantyne (2008_a)150 North America, South America, Europe Pharm. Fund Multicenter | Participants with increased ATP III risk adjusted non-HDL-c but on target LDL-c on run-in simvastatin 20 mg/day | Simvastatin 20 | Ext Rls 1000–2000 | 187 | Simvastatin 20 | 114 | 24 | | 0/0 | unclear | 3 | No
Ballantyne (2008_b)171 North America, South America, Pharm. Fund Multicenter | Participants with elevated non-HDL-c level desipte run-in simvastatin 40 mg/day | Simvastatin 40 | Ext Rls 1000–2000 | 216 | Simvastatin 80 | 119 | 24 | 104 | 0/0 | adequate | 3 | No
Moore (2007)162 North America, Pharm. Fund Single center | Participants with increased ATP III risk adjusted non-HDL-c but on target LDL-c on run-in simvastatin 20 mg/day | Atorvastatin 20 | Ext Rls | 41 | Atorvastatin 30 | 42 | 48 | 154 | 1/0 3.15 (0.12, 79.54) | unclear | 2 | Yes
Relative probability of participants experiencing elevated serum AST and/or ALT > 3 times ULN and/or hepatitis – Rosuvastatin - Lower dose statin in combination versus higher dose monotherapy
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 10 | Ex Rls 2000 | 80 | Rosuvastatin 40 | 46 | 24 | 145 | 0/0 | unclear | 2 | no
Relative probability of participants experiencing myalgia
Hunninghake (2003)128 North America Pharm. Fund Multicenter | Participants with type IIA hyperlipidemia or type IIB hyperlipidemia | Lovastatin 20–40 | Ex Rls 2000 | 114 | Lovastatin 40 | 61 | 28 | 189 | 5/4 0.65 (0.17, 2.53) | unclear | 4 | yes
Kos Pharm (MA-06)105 MA-06 North America Multicenter | Participants with hyperlipidemia type IIa or IIb, Statin naïve | Lovastatin 20–40 | Ex Rls 2000 | 114 | Lovastatin 40 | 61 | 28 | 189 | 5/7 0.35 (0.11, 1.17) | yes | 5 | no
Bays (2003_1)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels | Lovastatin 20–40 | Ex Rls 2000 | 78 | Simvastatin 10–40 | 76 | 16 | 192 | 0/0 | unclear | 1 | no
Bays (2003_2)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels | Lovastatin 20–40 | Ex Rls 2000 | 79 | Atorvastatin 10–40 | 82 | 16 | 192 | 0/1 0.34 (0.01, 8.51) | unclear | 1 | no
Relative probability of participants experiencing CPK greater than 10 times the upper limit of normal
Kos Pharm (MA-06)105 MA-06 North America Multicenter | Participants with hyperlipidemia type IIa or IIb, Statin naïve | Lovastatin 40 | Ex Rls 2000 | 114 | Lovastatin 40 | 61 | 28 | 189 | 0/0 | yes | 5 | no
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 10–40 | Ex Rls 2000 | 152 | Rosuvastatin 40 | 46 | 24 | 145 | 0/0 | unclear | 2 | no
Insull (2004)182 North America Pharm. Fund Multicenter | Participants with type IIa or IIb primary hyperlipidemia, statin naïve | Lovastatin 10–40 | Ex Rls 2500 | 100 | Lovastatin 40 | 33 | 20 | 198 | 0/0 | unclear | 2 | no
Kos Pharm (MA-14)104 MA-14 North America Multicenter | HC type IIa or IIb statin naive | Lovastatin 10–40 | Ex Rls | 100 | Lovastatin 40 | 33 | 20 | 198 | 0/0 | yes | 4 | no
Bays (2003_1)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels | Lovastatin 20–40 | Ex Rls 2000 | 78 | Simvastatin 10–40 | 76 | 16 | 192 | 0/0 | unclear | 1 | no
Bays (2003_1)49 ADVOCATE North America Pharm. Fund Multicenter | Participants with elevated LDL-c and decreased HDL-c blood levels | Lovastatin 20–40 | Ex Rls 2000 | 79 | Atorvastatin 10–40 | 82 | 16 | 192 | 0/0 | unclear | 1 | no
McKenney (2007_2)139 COMPELL study North America Pharm. Fund Multicenter | HC, heterogeneous 10-year CHD risk estimates | Mixed 20–40 | Ex Rls 2000 | 125 | Rosuvastatin 40 | 73 | 12 | 197 | 0/0 | unclear | 2 | no
Stein (1996)170 North America Pharm. Fund Multicenter | Participants with elevated low-density lipoprotein cholesterol, high triglycerides, and low high-density lipoprolein cholesteroL | Simvastatin 10 | Imm Rls 1500 | 60 | Simvastatin 10 | 60 | 17 | 176 | 0/0 | unclear | 2 | no
Moore (2007)162 North America, Pharm. Fund Single center | Participants with increased ATP III risk adjusted non-HDL-c but on target LDL-c on run-in simvastatin 20 mg/day | Atorvastatin 20 | Ext Rls | 41 | Atorvastatin 30 | 42 | 48 | 154 | 1/0 3.15 (0.12, 79.54) | unclear | 2 | Yes
Ballantyne (2008_b)171 North America, South America, Pharm. Fund Multicenter | Participants with elevated non-HDL-c level desipte run-in simvastatin 40 mg/day | Simvastatin 40 | Ext Rls 1000–2000 | 216 | Simvastatin 80 | 119 | 24 | 104 | 0/0 | adequate | 3 | No
Relative probability of participants experiencing CPK greater than 10 times the upper limit of normal – Rosuvastatin plus lower dose statin in combination versus higher dose monotherapy
Capuzzi (2003)155 4522IL/0029 North America Pharm. Fund Multicenter | Participants with combined dyslipidemia (Fredrickson’s type IIb or IV hyperlipidemia) | Rosuvastatin 10 | Ex Rls 2000 | 80 | Rosuvastatin 40 | 46 | 24 | 145 | 0/0 | unclear | 2 | no

## Included Evidence for Bile Acid Sequestrant plus Statin Therapy Compared With Statin Monotherapy

Table F-24

Longer-term outcomes (clinical outcomes, serious adverse events and cancer) using BAS plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | BAS (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Trial Baseline LDL-c (mg/dL) | Combo/mono: number of participants with events Odds ratio (95% CI) | AAC | Jadad Score | ITTA
All-cause Mortality, all trials
Sprecher (1994_1)52 North America Pharm. Fund Multicentre | Participants with moderate HC (LDL-c ≥ 160mg/dL), not on lipid- lowering medication | Fluvastatin 10 | C-amine 8–16 | 36 | Fluvastatin 10 | 39 | 24 | 209 | 0/1 0.35 (0.01, 8.9) | unclear | 3 | No
Sprecher (1994_2)52 North America Pharm. Fund Multicentre | Participants with moderate HC (LDL-c ≥160mg/dL), not on lipid- lowering medication | Fluvastatin 20 | C-amine 8–16 | 37 | Fluvastatin 20 | 38 | 24 | 209 | 0/0 | unclear | 3 | No
Knapp (2001_1)172 North America Pharm. Fund Multicentre | Participants with moderate HC (LDL-c ≥160mg/dL), statin naïve | Simvastatin 10 | C-lam 3.8 | 35 | Simvastatin 10 | 36 | 6 | 187 | 0/0 | yes | 5 | No
Knapp (2001_2)172 North America Pharm. Fund Multicentre | Participants with moderate HC (LDL-c ≥160mg/dL), statin naïve | Simvastatin 20 | C-lam 2.3 | 37 | Simvastatin 20 | 39 | 6 | 187 | 1/0 3.25 (0.13, 82.2) | yes | 5 | No
Davidson (2001) 185 North America Pharm. Fund Multicentre | Participants with moderate HC (LDL-c ≥160mg/dL) | Lovastatin 10 | C-lam 3.8 | 50 | Lovastatin 10 | 26 | 4 | 170 | 0/0 | unclear | 4 | No
Fatal myocardial infarction
Sprecher (1994_1)52 North America Pharm. Fund Multicentre | Participants with moderate HC (LDL-c ≥160mg/dL), not on lipid- lowering medication | Fluvastatin 10 | C-amine 8–16 | 36 | Fluvastatin 10 | 39 | 24 | 209 | 0/1 0.35 (0.01, 8.91) | unclear | 3 | No
Sprecher (1994_2)52 North America Pharm. Fund Multicentre | Participants with moderate HC (LDL-c ≥160mg/dL), not on lipid- lowering medication | Fluvastatin 20 | C-amine 8–16 | 37 | Fluvastatin 20 | 38 | 24 | 209 | 0/0 | unclear | 3 | No
Serious adverse event(s)
Simons (1998)198 The Six Cities Study Pharm. fund | Participants with severe HC (LDL-c ≥190 mg/dL) | Simvastatin 40 | C-amine 4 | 44 | Atorvastatin 80 | 92 | 30 | 343 | 1/5 0.40 (0.05, 3.6) | unclear | 1 | No
Knapp (2001)172 North America Pharm. Fund Multicentre | Participants with moderate HC (LDL-c ≥160mg/dL), statin naïve | Simvastatin 10–20 | C-lam 2.3–3.8 | 68 | Simvastatin 10–20 | 74 | 6 | 187 | 0/1 0.36 (0.01, 8.9) | yes | 5 | No

Table F-25

Surrogate outcome – Achieving ATP-III target LDL-c using BAS plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | BAS Max Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Trial Baseline LDL-c (mg/dL) | Combo/mono: number of participants with events Odds ratio (95% CI) | AAC | Jadad Score | ITTA
Ito (1996)108 North America Pharm. fund | Participants with moderate HC, history of CAD, all with prior statin use | Pravastatin 20 | C-amine 10 | 28 | Pravastatin 40 | 31 | 12 | 181 | 13/5 4.51 (1.34, 15.1) | unclear | 1 | no

Table F-26

Surrogate outcome, LDL-c using BAS plus statin therapy compared with statin monotherapy

Low density lipoprotein cholesterol
Trial | Population | Combination Statin Dose (mg/day) | BAS (g/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Mean Baseline LDL-c (mg/dL) | Combo- mono: mean difference (95% CI) | AAC | Jadad Score | ITTA
Combination – monotherapy: difference in mean percentage change from baseline
Hunninghake (2001)133 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Atorvastatin 10 | C-lam 3.8g | 18 | Atorvastatin 80 | 20 | 4 | 184 | 5 (−3.34, 13.34) | unclear | 4 | yes
O'Brien (1990)174 Pharm. Fund Multicenter | Participants with severe HC (LDL-c ≥215 mg/dL) or moderate HC + CAD | Simvastatin 40 | C-amine 24 | 35 | Simvastatin 40 | 15 | 40 | 298 | −10.10 (−19.92, − 0.3) | unclear | 1 | no
Isaacsohn (1997)163 North America Single centre | Heterogeneous familial and polygenic HC (LDL-c ≥220 mg/dL) | Mixed | C-pol 20 | 21 | Atorvastatin 80 | 16 | 32 | 291 | 5.43 (−1.84, 12.7) | unclear | 1 | no
Simons (1998)198 The Six Cities Study Pharm. fund | Participants with severe HC (LDL-c ≥190 mg/dL) | Simvastatin 40 | C-amine 4 | 44 | Atorvastatin 80 | 92 | 30 | 343 | 11.00 (6.45, 15.6) | unclear | 1 | no
Sprecher (1994_1)52 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL), not on lipid-lowering medication | Fluvastatin 10 | C-amine 8–16 | 35 | Fluvastatin 10 | 38 | 24 | 209 | −10.50 (−16.94, − 4.1) | unclear | 3 | no
Sprecher (1994_2)52 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL), not on lipid-lowering medication | Fluvastatin 20 | C-amine 8–16 | 35 | Fluvastatin 20 | 38 | 24 | 209 | −11.90 (−18.06, − 5.7) | unclear | 3 | no
PMSG II (1993)191 Pravastatin Multicenter Study Group II North America Pharm. fund | Participants with moderate HC (LDL-c ≥160mg/dL), excluding those with hypersensitivity to C- amine | Pravastatin 40 | C-amine 24 | 61 | Pravastatin 40 | 57 | 16–24 | 235 | −13.70 (−18.76, − 8.6) | unclear | 3 | no
Simons (1992)173 Europe Pharm. Fund Single centre | Participants with primary HC, already in use of statins | Simvastatin 40 | C-pol 5–10 | 39 | Simvastatin 40 | 22 | 12 | 290 | −11.34 (−17.82, − 4.9) | yes | 4 | no
Heinonen (1996)164 Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Atorvastatin 10 | C-pol 20 | 20 | Atorvastatin 10 | 41 | 11 | 211 | −10.00 (−16.95, − 3.0) | unclear | 1 | no
Ballantyne (2004_a)122 North America Pharm. Fund Multicenter | Participants with severe HC (LDL-c 190–400 mg/dL), all with prior statin use | Rosuvastatin 80 | C-amine 16 | 75 | Rosuvastatin 80 | 69 | 6 | 259 | −4.10 (−9.10, 0.9) | yes | 2 | no
Knapp (2001_1)172 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL), statin naïve | Simvastatin 10 | C-lam 3.8 | 34 | Simvastatin 10 | 35 | 6 | 187 | −16.00 (−22.50, − 9.5) | yes | 5 | no
Knapp (2001_2) 172 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL), statin naïve | Simvastatin 20 | C-lam 2.3 | 37 | Simvastatin 20 | 39 | 6 | 187 | −8.00 (−13.40, − 2.6) | yes | 5 | no
Hunninghake (2001)133 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Atorvastatin 10 | C-lam 3.8g | 18 | Atorvastatin 10 | 18 | 4 | 184 | −10.00 (−17.07, − 2.9) | unclear | 4 | yes
Davidson (2001)185 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Lovastatin 10 | C-lam 3.8g | 50 | Lovastatin 10 | 26 | 4 | 170 | −11.80 (−15.62, − 8.0) | unclear | 4 | no

Table F-27

Surrogate outcome – HDL-c using BAS plus statin therapy compared with statin monotherapy

High density lipoprotein cholesterol
Trial | Population | Combination Statin Dose (mg/day) | BAS (g/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Mean Baseline LDL-c (mg/dL) | Combo- mono: mean difference (95% CI) | AAC | Jadad Score | ITTA
Combination – monotherapy: difference in mean percentage change from baseline
Hunninghake (2001)133 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Atorvastatin 10 | C-lam 3.8g | 18 | Atorvastatin 80 | 20 | 4 | 184 | 5 (−3.34, 13.34) | unclear | 4 | yes
O'Brien (1990)174 Pharm. Fund Multicenter | Participants with severe HC (LDL-c ≥215 mg/dL) or moderate HC + CAD | Simvastatin 40 | C-amine 24 | 35 | Simvastatin 40 | 15 | 40 | 298 | −3.10 (−19.49, 13.29) | unclear | 1 | no
Isaacsohn (1997)163 North America Single · centre | Heterogeneous familial and polygenic HC (LDL-c ≥220 mg/dL) | Mixed | C-pol 20 | 21 | Atorvastatin 80 | 16 | 32 | 291 | 7.66 (−2.04, 17.4) | unclear | 1 | no
Simons (1998)198 The Six Cities Study Pharm. fund | Participants with severe HC (LDL-c ≥190 mg/dL) | Simvastatin 40 | C-amine 4 | 44 | Atorvastatin 80 | 92 | 30 | 343 | 3.00 (−0.39, 6.4) | unclear | 1 | no
Sprecher (1994_1)52 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL), not on lipid-lowering medication | Fluvastatin 10 | C-amine 8–16 | 35 | Fluvastatin 10 | 38 | 24 | 209 | −2.60 (−8.47, 3.3) | unclear | 3 | no
Sprecher (1994_2)52 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL), not on lipid-lowering medication | Fluvastatin 20 | C-amine 8–16 | 35 | Fluvastatin 20 | 38 | 24 | 209 | −5.70 (−10.78, − 0.6) | unclear | 3 | no
PMSG II (1993)191 Pravastatin Multicenter Study Group II North America Pharm. fund | Participants with moderate HC (LDL-c ≥160mg/dL), excluding those with hypersensitivity to C- amine | Pravastatin 40 | C-amine 24 | 61 | Pravastatin 40 | 119 | 16–24 | 235 | 0.77 (−4.02, 5.6) | unclear | 3 | no
Simons (1992)173 Europe Pharm. Fund Single centre | Participants with primary HC, already in use of statins | Simvastatin 40 | C-pol 5–10 | 39 | Simvastatin 40 | 22 | 12 | 290 | 4.50 (−2.50, 11.5) | yes | 4 | no
Heinonen (1996)164 Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Atorvastatin 10 | C-pol 20 | 40 | Atorvastatin 10 | 41 | 11 | 211 | 1.00 (−6.03, 8.0) | unclear | 1 | no
Ballantyne (2004_a)122 North America Pharm. Fund Multicenter | Participants with severe HC (LDL-c 190–400 mg/dL), all with prior statin use | Rosuvastatin 80 | C-amine 16 | 75 | Rosuvastatin 80 | 69 | 6 | 259 | −1.00 (−6.68, 4.68) | yes | 2 | no
Davidson (2001)185 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Lovastatin 10 | C-lam 3.8g | 50 | Lovastatin 10 | 26 | 4 | 170 | 0.00 (−4.77, 4.8) | unclear | 4 | no

Table F-28

Adverse events and adherence to treatment using BAS plus statin compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | BAS Max Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow- up (wk) | Trial Baseline LDL-c (mg/dL) | Combo/mono: number of participants with events Odds ratio (95% CI) | AAC | Jadad Score | ITTA
Relative probability of participants adhering to treatment
Eriksson (1998)190 PaCt trial Europe Pharm. Fund Multicenter | Participants with 1^o^ HC, heterogeneous CHD risk estimates | Pravastatin 20 | C-amine 8–16 | 261 | Pravastatin 20–40 | 812 | 96 | 212 | 227/765 0.41 (0.26, 0.65) | yes | 3 | no
Heinonen (1996)164 Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Atorvastatin 10 | C-pol 20 | 20 | Atorvastatin 10 | 42 | 12 | 211 | 15/38 0.32 (0.07, 1.34) | unclear | 1 | no
Ballantyne (2004_a)122 North America Pharm. Fund Multicenter | Participants with severe HC (LDL-c 190–400 mg/dL), all with prior statin use | Rosuvastatin 80 | C-amine 16 | 75 | Rosuvastatin 80 | 69 | 6 | 259 | 38/63 0.10 (0.04, 0.25) | yes | 2 | no
Johansson (1995)137 Europe Pharm. Fund Multicenter | Participants with moderate to severe HC | Simvastatin 20 | C-pol 5–10 | 57 | Simvastatin 40 | 26 | 4–12 | 221 | 41/23 0.33 (0.09, 1.27) | unclear | 2 | no
Hunninghake (2001)133 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Atorvastatin 10 | C-lam 3.8g | 19 | Atorvastatin 10–80 | 39 | 4 | 184 | 17/35 0.97 (0.16, 5.84) | unclear | 4 | yes
Hunninghake (2001)133 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Atorvastatin 10 | C-lam 3.8g | 19 | Atorvastatin 80 | 20 | 4 | 184 | 17/18 0.94 (0.12, 7.5) | unclear | 4 | yes
Relative probability of participants experiencing an adverse event
Sprecher (1994_1)52 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL), not on lipid- lowering medication | Fluvastatin 10 | C-amine 8–16 | 36 | Fluvastatin 10 | 39 | 24 | 209 | 31/18 7.23 (2.32, 22.5) | unclear | 3 | no
Sprecher (1994_2)52 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL), not on lipid- lowering medication | Fluvastatin 20 | C-amine 8–16 | 37 | Fluvastatin 20 | 38 | 24 | 209 | 30/20 3.86 (1.36, 10.9) | unclear | 3 | no
Ballantyne (2004)122 North America Pharm. Fund Multicenter | Participants with severe HC (LDL-c 190–400 mg/dL), all with prior statin use | Rosuvastatin 80 | C-amine 16 | 76 | Rosuvastatin 80 | 71 | 6 | 259 | 42/25 2.27 (1.17, 4.4) | yes | 2 | no
Knapp (2001_1)172 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL), statin naïve | Simvastatin 10 | C-lam 3.8 | 34 | Simvastatin 10 | 35 | 6 | 187 | 21/22 0.95 (0.36, 2.5) | yes | 5 | no
Knapp (2001_2)172 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL), statin naïve | Simvastatin 20 | C-lam 2.3 | 34 | Simvastatin 20 | 39 | 6 | 187 | 25/23 1.93 (0.72, 5.2) | yes | 5 | no
Johansson (1995)137 Europe Pharm. Fund Multicenter | Participants with moderate to severe HC | Simvastatin 20 | C-pol 5–10 | 57 | Simvastatin 40 | 26 | 4–12 | 221 | 31/13 1.19 (0.47, 3.0) | unclear | 2 | no
Relative probability of participants withdrawing from treatment due to an adverse event
Simons (1998)198 The Six Cities Study Pharm. fund | Participants with severe HC (LDL-c ≥190 mg/dL) | Simvastatin 40 | C-amine 4 | 44 | Atorvastatin 80 | 92 | 30 | 343 | 6/1 14.37 (1.67, 123.4) | unclear | 1 | no
Sprecher (1994)52 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL), not on lipid- lowering medication | Fluvastatin 10–20 | C-amine 8–16 | 73 | Fluvastatin 10–20 | 77 | 24 | 209 | 1/4 0.25 (0.03, 2.32) | unclear | 3 | no
PMSG II (1993)191 Pravastatin Multicenter Study Group II North America Pharm. fund | Participants with moderate HC (LDL-c ≥160mg/dL), excluding those with hypersensitivity to C-amine | Pravastatin 40 | C-amine 24 | 64 | Pravastatin 40–80 | 126 | 16–24 | 235 | 1/2 0.98 (0.09, 11.1) | unclear | 3 | no
Heinonen (1996)164 Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Atorvastatin 10 | C-pol 20 | 20 | Atorvastatin 10 | 42 | 12 | 211 | 0/1 0.67 (0.03, 17.3) | unclear | 1 | no
Ballantyne (2004_a)122 North America Pharm. Fund Multicenter | Participants with severe HC (LDL-c 190–400 mg/dL), all with prior statin use | Rosuvastatin 80 | C-amine 16 | 76 | Rosuvastatin 80 | 71 | 6 | 259 | 2/0 4.80 (0.23, 101.7) | yes | 2 | no
Knapp (2001_1)172 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL), statin naïve | Simvastatin 10 | C-lam 3.8 | 35 | Simvastatin 10 | 36 | 6 | 187 | 1/1 1.03 (0.06, 17.1) | yes | 5 | no
Knapp (2001_2)172 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL), statin naïve | Simvastatin 20 | C-lam 2.3 | 37 | Simvastatin 20 | 39 | 6 | 187 | 3/0 8.01 (0.40, 160.7) | yes | 5 | no
Davidson (2001)185 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Atorvastatin 10 | C-lam 3.8 | 50 | Atorvastatin 10–80 | 26 | 4 | 170 | 4/0 5.13 (0.27, 99.0) | unclear | 4 | no
Hunninghake (2001)133 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Lovastatin 10 | C-lam 3.8 | 19 | Lovastatin 10 | 39 | 4 | 184 | 1/3 0.67 (0.06, 6.9) | unclear | 4 | yes
Hunninghake (2001)133 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Atorvastatin 10 | C-lam 3.8g | 19 | Atorvastatin 80 | 20 | 4 | 184 | 1/1 1.06 (0.06, 18.2) | unclear | 4 | yes
Relative probability of participants experiencing elevated serum AST and/or ALT > 3 times ULN and/or hepatitis
Simons (1998)198 The Six Cities Study Pharm. fund | Participants with severe HC (LDL-c ≥190 mg/dL) | Simvastatin 40 | C-amine 4 | 44 | Atorvastatin 80 | 92 | 30 | 343 | 0/0 | unclear | 1 | no
Davidson (2001)185 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Lovastatin 10 | C-lam 3.8g | 50 | Lovastatin 10 | 26 | 4 | 170 | 0/0 | unclear | 4 | no
Relative probability of participants experiencing myalgia
Ito (1997)108 North America Pharm. fund | Participants with moderate HC, history of CAD, all with prior statin use | Pravastatin 20 | C-amine 10 | 28 | Pravastatin 40 | 31 | 12 | 181 | 0/3 0.14 (0.01, 2.9) | unclear | 1 | no
Simons (1992)173 Europe Pharm. Fund Single centre | Participants with primary HC, already in use of statins | Simvastatin 40 | C-pol 5–10 | 39 | Simvastatin 40 | 22 | 12 | 290 | 1/1 0.55 (0.03, 9.3) | unclear | 4 | no
Ballantyne (2004)122 | Participants with severe HC (LDL-c 190–400 mg/dL), all with prior statin use | Rosuvastatin 80 | C-amine 16 | 76 | Rosuvastatin 80 | 71 | 6 | 259 | 1/0 2.84 (0.11, 70.9) | yes | 2 | no
Davidson (2001)185 North America Pharm. Fund Multicenter | Participants with moderate HC (LDL-c ≥160mg/dL) | Lovastatin 10 | C-lam 3.8g | 50 | Lovastatin 10 | 26 | 4 | 170 | 2/3 0.32 (0.05, 2.0) | unclear | 4 | no
Relative probability of participants experiencing CPK greater than 10 times the upper limit of normal
Simons (1998)198 The Six Cities Study Pharm. fund | Participants with severe HC (LDL-c ≥190 mg/dL) | Simvastatin 40 | C-amine 4 | 44 | Atorvastatin 80 | 92 | 30 | 343 | 0/0 | unclear | 1 | no
Ballantyne (2004)122 North America Pharm. Fund Multicenter | Participants with severe HC (LDL-c 190–400 mg/dL), all with prior statin use | Rosuvastatin 80 | C-amine 16 | 76 | Rosuvastatin 80 | 71 | 6 | 259 | 0/0 | yes | 2 | no

## Included Evidence for Omega-3 Fatty Acid Plus Statin Therapy Compared With Statin Monotherapy

Table F-29

Longer-term outcomes (clinical outcomes, serious adverse events and cancer) using omega-3 fatty acid plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow-up (wk) | Trial Baseline LDL-c (mg/dL) | Combo/mono: number of participants with events Odds ratio (95% CI) | AAC | Jadad Score | ITTA
All-cause mortality
Yokoyama (2007)141 JELIS Asia Pharm. Fund Multicenter | Participants with hypercholesterolemia in Japan | Mixed 5–20 | 9326 | Mixed 5–20 | 9319 | 240 | 182 | 286/265 1.08 (0.91, 1.28) | yes | 2 | yes
Davidson (2007)180 COMBOS trial North America Pharm. Fund Multicenter | Participants with persisting hypertriglyceridemia despite receiving simvastatin | Simvastatin 40 | 122 | Simvastatin 40 | 132 | 8 | 91 | 0/0 | yes | 4 | no
Nordoy (1998)177 Europe Pharm. Fund Single centre | Participants with combined hyperlipidemia and statin naïve | Simvastatin 20 | 21 | Simvastatin 20 | 20 | 5 | 161 | 0/0 | unclear | 4 | no
All-cause mortality – 24 weeks or more
Yokoyama (2007)141 JELIS Asia Pharm. Fund Multicenter | Participants with hypercholesterolemia in Japan | Mixed 5–20 | 9326 | Mixed 5–20 | 9319 | 240 | 182 | 286/265 1.08 (0.91, 1.28) | yes | 2 | yes
All-cause mortality – adequate allocation concealment
Yokoyama (2007)141 JELIS Asia Pharm. Fund Multicenter | Participants with hypercholesterolemia in Japan | Mixed 5–20 | 9326 | Mixed 5–20 | 9319 | 240 | 182 | 286/265 1.08 (0.91, 1.28) | yes | 2 | yes
Davidson (2007)180 COMBOS trial North America Pharm. Fund Multicenter | Participants with persisting hypertriglyceridemia despite receiving simvastatin | Simvastatin 40 | 122 | Simvastatin 40 | 132 | 8 | 91 | 0/0 | yes | 4 | no
All-cause mortality – Asian
Yokoyama (2007)141 JELIS Asia Pharm. Fund Multicenter | Participants with hypercholesterolemia in Japan | Mixed 5–20 | 9326 | Mixed 5–20 | 9319 | 240 | 182 | 286/265 1.08 (0.91, 1.28) | yes | 2 | yes
Fatal Myocardial Infarction – Participants requiring intensive lipid lowering therapy
Durrington (2001)176 Europe Pharm. Fund Single centre | Participants with CHD and persisting hypertriglyceridemia, despite receiving simvastatin. | Simvastatin 20–40 | 29 | Simvastatin 20–40 | 26 | 24 | 149 | 0/1 0.12 (0.00, 6.11) | unclear | 3 | no
Fatal Myocardial Infarction
Yokoyama (2007)141 JELIS Asia Pharm. Fund Multicenter | Participants with hypercholesterolemia in Japan | Mixed 5–20 | 9326 | Mixed 5–20 | 9319 | 240 | 182 | 11/14 0.79 (0.36, 1.72) | yes | 2 | yes
Durrington (2001)176 Europe Pharm. Fund Single centre | Participants with CHD and persisting hypertriglyceridemia, despite receiving simvastatin. | Simvastatin 20–40 | 29 | Simvastatin 20–40 | 26 | 24 | 149 | 0/1 0.12 (0.00, 6.11) | unclear | 3 | no
Non-fatal myocardial infarction
Yokoyama (2007)141 JELIS Asia Pharm. Fund Multicenter | Participants with hypercholesterolemia in Japan | Mixed 5–20 | 9326 | Mixed 5–20 | 9319 | 240 | 182 | 62/83 0.75 (0.54, 1.03) | yes | 2 | yes
Any myocardial infarction
Yokoyama (2007)141 JELIS Asia Pharm. Fund Multicenter | Participants with hypercholesterolemia in Japan | Mixed 5–20 | 9326 | Mixed 5–20 | 9319 | 240 | 182 | 71/93 0.76 (0.56, 1.04) | yes | 2 | yes
Hemorrhagic stroke
Yokoyama (2007)141 JELIS Asia Pharm. Fund Multicenter | Participants with hypercholesterolemia in Japan | Mixed 5–20 | 9326 | Mixed 5–20 | 9319 | 240 | 182 | 49/39 0.42 (0.10, 1.87) | yes | 2 | yes
Ischemic stroke
Yokoyama (2007)141 JELIS Asia Pharm. Fund Multicenter | Participants with hypercholesterolemia in Japan | Mixed 5–20 | 9326 | Mixed 5–20 | 9319 | 240 | 182 | 115/123 0.93 (0.72, 1.21) | yes | 2 | yes
Any stroke
Yokoyama (2007)141 JELIS Asia Pharm. Fund Multicenter | Participants with hypercholesterolemia in Japan | Mixed 5–20 | 9326 | Mixed 5–20 | 9319 | 240 | 182 | 166/162 1.02 (0.82, 1.27) | yes | 2 | yes
Serious adverse events
Davidson (2007)180 COMBOS trial North America Pharm. Fund Multicenter | Participants with persisting hypertriglyceridemia despite receiving simvastatin | Simvastatin 40 | 122 | Simvastatin 40 | 132 | 8 | 91 | 4/1 4.44 (0.49, 40.29) | yes | 4 | no
Cancer
Yokoyama (2007)141 JELIS Asia Pharm. Fund Multicenter | Participants with hypercholesterolemia in Japan | Mixed 5–20 | 9326 | Mixed 5–20 | 9319 | 240 | 182 | 242/218 1.11 (0.92, 1.34) | yes | 2 | yes

Table F-30

Surrogate outcome, LDL-c using omega-3 fatty acid plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow-up (wk) | Trial Baseline LDL-c (mg/dL) | Combo/mono: number of participants with events Odds ratio (95% CI) | AAC | Jadad Score | ITTA
Difference in mean percentage change from baseline
Davidson (2007)180 COMBOS trial North America Pharm. Fund Multicenter | Participants with persisting hypertriglyceridemia despite receiving simvastatin | Simvastatin 40 | 122 | Simvastatin 40 | 132 | 8 | 91 | 5.30 (1.45, 9.15) | yes | 4 | No
Chan (2002)107 Australia Pharm. Fund Single centre | Participants were non-diabetic, dyslipidemic men with visceral obesity (BMI >29) | Atorvastatin 40 | 11 | Atorvastatin 40 | 13 | 6 | 152 | 5.1 (−3.04, 13.24) | unclear | 4 | No

Table F-31

Surrogate outcome – HDL-c using omega-3 fatty acid plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow-up (wk) | Trial Baseline LDL-c (mg/dL) | Difference (95% CI) [combo-mono] | AAC | Jadad Score | ITTA
Difference in percentage change from baseline HDL-c
Davidson (2007)180 COMBOS trial North America Pharm. Fund Multicenter | Participants with persisting hypertriglyceridemia despite receiving simvastatin | Simvastatin 40 | 122 | Simvastatin 40 | 132 | 8 | 91 | 5.20 (2.95, 7.45) | yes | 4 | No
Chan (2002)107 Australia Pharm. Fund Single centre | Participants were non-diabetic, dyslipidemic men with visceral obesity (BMI >29) | Atorvastatin 40 | 11 | Atorvastatin 40 | 13 | 6 | 152 | 9.50 (−0.42, 19.42) | unclear | 4 | No
Davidson (1997)178 North America Single centre | Participants with combined hyperlipidemia | Simvastatin 10 | 9 | Simvastatin 10 | 10 | 6–12 | | 3.20 (−6.76, 13.16) | unclear | 2 | No

Table F-32

Surrogate outcome – TC:HDL-c ratio using omega-3 fatty acid plus statin therapy compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow-up (wk) | Trial Baseline LDL-c (mg/dL) | Combo/mono: number of participants with events Odds ratio (95% CI) | AAC | Jadad Score | ITTA
Difference in mean percentage change in TC:HDL-c ratio
Davidson (2007)180 COMBOS trial North America Pharm. Fund Multicenter | Participants with persisting hypertriglyceridemia despite receiving simvastatin | Simvastatin 40 | 122 | Simvastatin 40 | 132 | 8 | 91 | −8.10 (−10.69, −5.51) | yes | 4 | No
Davidson (1997)178 North America Single centre | Participants with combined hyperlipidemia | Simvastatin 10 | 9 | Simvastatin 10 | 10 | 6–12 | | −3.10 (−12.84, 6.64) | unclear | 2 | No

Table F-33

Adverse events and adherence to treatment using omega-3 fatty acid plus statin compared with statin monotherapy

Trial | Population | Combination Statin Dose (mg/day) | Omega-3 FA Max Dose (mg/day) | Combo N | Monotherapy Statin Dose (mg/day) | Mono N | Follow up (wk) | Trial Baseline LDL-c (mg/dL) | Number of Events Odds Ratio (95% CI) [combo/mono] | AAC | Jadad Score | ITTA
Relative probability of participants experiencing an adverse event
Yokoyama (2007)141 JELIS Asia Pharm. Fund Multicenter | Participants with hypercholesterolemia in Japan | Mixed 5–20 | 1800 | 9326 | Mixed 5–20 | 9319 | 240 | 182 | 2334/2004 1.22 (1.14, 1.30) | yes | 2 | yes
Durrington (2001)176 Europe Pharm. Fund Single centre | Participants with CHD and persisting hypertriglyceridemia, despite receiving simvastatin. | Simvastatin 20–40 | 4000 | 29 | Simvastatin 10–40 | 26 | 24 | 149 | 22/17 1.66 (0.51, 5.38) | unclear | 3 | no
Liu (2003)179 Europe Single centre | Participants with hyperlipidemia and statin naïve | Simvastatin 10 | 9200 | 19 | Simvastatin 10 | 18 | 12 | 173 | 0/0 | unclear | 1 | no
Davidson (2007)180 COMBOS trial North America Pharm. Fund Multicenter | Participants with persisting hypertriglyceridemia despite receiving simvastatin | Simvastatin 40 | 4000 | 122 | Simvastatin 40 | 132 | 8 | 91 | 51/63 0.79 (0.48, 1.29) | yes | 4 | no
Nordoy (2001)165 Europe Single centre | Participants with combined hyperlipidemia and total cholesterol >200 mg/dL. | Atorvastatin 10 | 2000 | 22 | Atorvastatin 10 | 20 | 5 | 197 | 0/0 | unclear | 4 | yes
Nordoy (1998)177 Europe Pharm. Fund Single centre | Participants with combined hyperlipidemia and statin naïve | Simvastatin 20 | 4000 | 21 | Simvastatin 20 | 20 | 5 | 161 | 0/0 | unclear | 4 | no
Relative probability of participants experiencing an adverse event - Trials 24 weeks or longer
Yokoyama (2007)141 JELIS Asia Pharm. Fund Multicenter | Participants with hypercholesterolemia in Japan | Mixed 5–20 | 1800 | 9326 | Mixed 5–20 | 9319 | 240 | 182 | 2334/2004 1.22 (1.14, 1.30) | yes | 2 | yes
Durrington (2001)176 Europe Pharm. Fund Single centre | Participants with CHD and persisting hypertriglyceridemia, despite receiving simvastatin. | Simvastatin 20–40 | 4000 | 29 | Simvastatin 10–40 | 26 | 24 | 149 | 22/17 1.66 (0.51, 5.38) | unclear | 3 | no
Relative probability of participants withdrawing from treatment due to an adverse event
Davidson (2007) 180 COMBOS trial North America Pharm. Fund Multicenter | Participants with persisting hypertriglyceridemia despite receiving simvastatin | Simvastatin 40 | 4000 | 122 | Simvastatin 40 | 133 | 8 | 91 | 3/3 1.09 (0.22, 5.52) | yes | 4 | no
Relative probability of participants experiencing elevated serum AST and/or ALT > 3 times ULN and/or hepatitis
Davidson (2007)180 COMBOS trial North America Pharm. Fund Multicenter | Participants with persisting hypertriglyceridemia despite receiving simvastatin | Simvastatin 40 | 4000 | 122 | Simvastatin 40 | 132 | 8 | 91 | 0/0 | yes | 4 | no
Nordoy (2001)165 Europe Single centre | Participants with combined hyperlipidemia and total cholesterol >200 mg/dL. | Atorvastatin 10 | 2000 | 22 | Atorvastatin 10 | 20 | 5 | 197 | 0/0 | unclear | 4 | yes
Nordoy (1998)177 Europe Pharm. Fund Single centre | Participants with combined hyperlipidemia and statin naïve | Simvastatin 20 | 4000 | 21 | Simvastatin 20 | 20 | 5 | 161 | 0/0 | unclear | 4 | no
Relative probability of participants experiencing CPK greater than 10 times the upper limit of normal
Davidson (2007)180 COMBOS trial North America Pharm. Fund Multicenter | Participants with persisting hypertriglyceridemia despite receiving simvastatin | Simvastatin 40 | 4000 | 122 | Simvastatin 40 | 132 | 8 | 91 | 0/0 | yes | 4 | no
Nordoy (2001)165 Europe Single centre | Participants with combined hyperlipidemia and total cholesterol >200 mg/dL. | Atorvastatin 10 | 2000 | 22 | Atorvastatin 10 | 20 | 5 | 197 | 0/0 | unclear | 4 | yes
Nordoy (1998)177 Europe Pharm. Fund Single centre | Participants with combined hyperlipidemia and statin naïve | Simvastatin 20 | 4000 | 21 | Simvastatin 20 | 20 | 5 | 161 | 0/0 | unclear | 4 | no
Relative probability of participants experiencing rhabdomyolysis (investigator defined)
Davidson (2007)180 COMBOS trial North America Pharm. Fund Multicenter | Participants with persisting hypertriglyceridemia despite receiving simvastatin | Simvastatin 40 | 4000 | 122 | Simvastatin 40 | 132 | 8 | 91 | 0/0 | yes | 4 | no