# Appendix E Within-Trial, Within-Treatment Pooling of Multiple Treatment Group Data

These tables present a summary of pooling undertaken during the present work. Pooling by authors of manuscripts was also incorporated in data syntheses, but is not summarized here.

Arms in bold type were used in data syntheses.

Arms in “plain type” were not used in data syntheses.

Arms in italics were pooled in the course of this work. Pooled arms were comprised of the arms immediately above. Pooled arms used in data syntheses (in bold print) were within the a priori acceptable limits for heterogeneity (I2 or Chi2 statistics ≤ 50%; p-value ≥ 0.05 as appropriate).

When more than one comparator arm is in bold, different arms were used depending upon the analysis. Doses were matched for global (“all participants, all doses”) analyses, while higher monotherapy doses were used to assess the benefits and harms of increasing the statin dose compared with adding a nonstatin medication.

Abbreviations
C-amine: colestyramine
C-lam: colesevelam
C-pol: colesipol
ER: extended release

Table E-1

Within-trial, within-treatment pooling of multiple treatment group data for clinical outcomes

Outcome / Trial | Statin Dose (mg/day) | Non-statin drug Dose (mg/day) | Number of participants
All cause mortality
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 53
| Rosuvastatin 10 | Fenofibrate 67 | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 5–10 | Fenofibrate 67 | 113
Davidson (2001) 185 | Lovastatin 10 | NONE | 26
| Lovastatin 10 | C-lam 2300 | 23
| Lovastatin 10 | C-lam 2300 | 27
| Lovastatin 10 | C-lam 2300 | 50
Constance (2007) 194 | Atorvastatin 20 | NONE | 219
| Simvastatin 20 | Ezetimibe 10 | 220
| Simvastatin 40 | Ezetimibe 10 | 222
| Simvastatin 20–40 | Ezetimibe 10 | 442
Kos Pharm (MA-14) 104 | Lovastatin 40 | NONE | 33
| Lovastatin 20 | Niacin (ER) 2500 | 34
| Lovastatin 40 | Niacin (ER) 2500 | 32
| Lovastatin 10 | Niacin (ER) 2500 | 34
| Lovastatin 10 | Niacin (ER) 2500 | 100
Kos Pharm (MA-06) 105 | Lovastatin 40 | NONE | 61
| Lovastatin 20 | Niacin (ER) 1000 | 57
| Lovastatin 40 | Niacin (ER) 2000 | 57
| Lovastatin 40 | Niacin (ER) 1000–2000 | 114
Ballantyne (2008) 150 | Simvastatin 20 | NONE | 114
| Simvastatin 20 | Niacin (ER) 1000 | 123
| Simvastatin 20 | Niacin (ER) 2000 | 64
| Simvastatin 20 | Niacin (ER) 1000–2000 | 187
Ballantyne (2008) 171 | Simvastatin 20 | NONE | 119
| Simvastatin 20 | Niacin (ER) 1000 | 116
| Simvastatin 20 | Niacin (ER) 2000 | 100
| Simvastatin 20 | Niacin (ER) 1000–2000 | 216
All cause mortality - Lower dose statin plus nonstatin in combination compared with higher dose monotherapy using the same statin
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 53
| Rosuvastatin 10 | Fenofibrate 67 | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 5–10 | Fenofibrate 67 | 113
All-cause mortality in participants with diabetes mellitus
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 53
| Rosuvastatin 10 | Fenofibrate 67 | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 5–10 | Fenofibrate 67 | 113
Constance (2007) 194 | Atorvastatin 20 | NONE | 219
| Simvastatin 40 | Ezetimibe 10 | 222
| Simvastatin 20 | Ezetimibe 10 | 220
| Simvastatin 20–40 | Ezetimibe 10 | 442
Fatal myocardial infarction
Kos Pharm (MA-06) 105 | Lovastatin 40 | NONE | 61
| Lovastatin 20 | Niacin (ER) 1000 | 57
| Lovastatin 40 | Niacin (ER) 2000 | 57
| Lovastatin 40 | Niacin (ER) 1000–2000 | 114
Vascular death
Hunninghake (2003) 128 | Lovastatin 40 | NONE | 61
| Lovastatin 20 | Niacin (ER) 1000 | 57
| Lovastatin 40 | Niacin (ER) 2000 | 57
| Lovastatin 40 | Niacin (ER) 1000–2000 | 114

Abbreviations: C-amine = colestyramine, C-lam = colesevelam, C-pol = colesipol, ER = extended release

Table E-2

Within-trial, within-treatment pooling of multiple treatment group data for surrogate outcomes

Outcome / Trial | Statin Dose (mg/day) | Non-statin drug Dose (mg/day) | Number of participants
Achieving ATP III target
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 50
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 53
| Rosuvastatin 5–40 | Fenofibrate 67 | 113
Constance (2007) 194 | Atorvastatin 20 | NONE | 219
| Simvastatin 40 | Ezetimibe 10 | 220
| Simvastatin 20 | Ezetimibe 10 | 222
| Simvastatin 20–40 | Ezetimibe 10 | 442
Feldman (2004) 47 | Simvastatin 40 | NONE | 248
| Simvastatin 10 | Ezetimibe 10 | 245
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 451
Achieving ATP III targets - participants with CAD
Bays (2003) 49 | Atorvastatin 40 | NONE | 16
| Simvastatin 40 | NONE | 18
| Mixed | NONE | 34
| Lovastatin 40 | Niacin (ER) 2000 | 17
| Lovastatin 40 | Niacin (ER) 1000 | 15
| Lovastatin 40 | Niacin (ER) 1000–2000 | 32
Achieving ATP III targets - participants with diabetes mellitus
Durrington (2004) 125 | Rosuvastatin | NONE | 50
| Rosuvastatin 10 | Fenofibrate 67 | 50
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 5–10 | Fenofibrate 67 | 110
Goldberg (2006) 144 | Atorvastatin 20 | NONE | 240
| Atorvastatin 10 | NONE | 237
| Atorvastatin | NONE | 241
| Simvastatin 10 | Ezetimibe 10 | 242
| Simvastatin 10 | Ezetimibe 10 | 238
| Simvastatin 10 | Ezetimibe 10 | 480
Constance (2007) 194 | Atorvastatin | NONE | 219
| Simvastatin 10 | Ezetimibe 10 | 222
| Simvastatin 10 | Ezetimibe 10 | 220
| Simvastatin 10 | Ezetimibe 10 | 442
Goldberg (2006) 144 | Atorvastatin 10 | NONE | 237
| Atorvastatin 20 | NONE | 240
| Atorvastatin 40 | NONE | 241
| Atorvastatin 10–40 | NONE | 718
| Simvastatin 20 | Ezetimibe 10 | 238
| Simvastatin 40 | Ezetimibe 10 | 242
| Simvastatin 20–40 | Ezetimibe 10 | 480
LDL-c
Feldman (2004) 47 | Simvastatin 40 | NONE | 248
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 10 | Ezetimibe 10 | 245
| Simvastatin 10–40 | Ezetimibe 10 | 451
Insull (2004) 182 | Lovastatin 40 | NONE | 33
| Lovastatin 40 | Niacin (ER) 2500 | 32
| Lovastatin 20 | Niacin (ER) 2500 | 34
| Lovastatin 10 | Niacin (ER) 2500 | 34
| Lovastatin 10–40 | Niacin (ER) 2500 | 100
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 51
| Rosuvastatin 10 | Fenofibrate 67 | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 5–10 | Fenofibrate 67 | 113
Capuzzi (2003) 155 | Rosuvastatin 40 | NONE | 46
| Rosuvastatin 10 | Niacin (ER) 2000 | 78
| Rosuvastatin 40 | Niacin (ER) 1000 | 71
| Rosuvastatin 10–40 | Niacin (ER) 1000–2000 | 71
Gagne (2002) 132 | Atorvastatin 80 | NONE | 12
| Simvastatin 80 | NONE | 5
| Mixed 80 | NONE | 17
| Atorvastatin 40 | Ezetimibe 10 | 12
| Simvastatin 40 | Ezetimibe 10 | 4
| Atorvastatin 80 | Ezetimibe 10 | 12
| Simvastatin 80 | Ezetimibe 10 | 5
| Mixed 40–80 | Ezetimibe 10 | 33
Hunninghake (2001) 133 | Atorvastatin 10 | NONE | 18
| Atorvastatin 80 | NONE | 20
| Atorvastatin 10–80 | NONE | 38
| Atorvastatin 10 | C-lam 3800 | 18
Davidson (2001) 185 | Lovastatin 10 | NONE | 26
| Lovastatin 10 | C-lam 2300 | 23
| Lovastatin 10 | C-lam 2300 | 27
Knapp (2001) 172 | Lovastatin 10 | C-lam 2300 | 50
| Simvastatin 20 | C-lam 2300 | 37
| Simvastatin 10 | C-lam 3800 | 34
| Simvastatin 10–20 | C-lam 2300–3800 | 71
| Simvastatin 20 | NONE | 39
| Simvastatin 10 | NONE | 35
| Simvastatin 10–20 | NONE | 74
Sprecher (1994) 52 | Fluvastatin 20 | NONE | 38
| Fluvastatin 10 | NONE | 38
| Fluvastatin 10–20 | NONE | 76
Sprecher (1994) 52 | Fluvastatin 20 | C-amine 16000 | 35
| Fluvastatin 10 | C-amine 16000 | 35
| Fluvastatin 10–20 | C-amine 16000 | 70
PMSG II (1993) 191 | Pravastatin 80 | NONE | 62
| Pravastatin 40 | NONE | 57
| Pravastatin 40–80 | NONE | 119
Simons (1992) 173 | Pravastatin 40 | C-amine 24000 | 61
| Simvastatin 40 | NONE | 22
| Simvastatin 40 | C-pol 5000 | 19
| Simvastatin 40 | C-pol 10000 | 20
| Simvastatin 40 | C-pol 5000–10000 | 39
McKenney (2007_2) 139 | Rosuvastatin 40 | NONE | 73
| Atorvastatin 40 | Niacin (ER) 2000 | 60
| Atorvastatin 20 | Niacin (ER) 1000 | 65
| Mixed 20–40 | Niacin (ER) 1000–2000 | 125
Goldberg (2006) 144 | Atorvastatin 20 | NONE | 240
| Atorvastatin 10 | NONE | 237
| Atorvastatin 40 | NONE | 241
| Atorvastatin 10–40 | NONE | 718
| Simvastatin 40 | Ezetimibe 10 | 242
| Simvastatin 20 | Ezetimibe 10 | 238
| Simvastatin 20–40 | Ezetimibe 10 | 480
Constance (2007) 194 | Atorvastatin 20 | NONE | 213
| Simvastatin 40 | Ezetimibe 10 | 215
| Simvastatin 20 | Ezetimibe 10 | 210
| Simvastatin 20–40 | Ezetimibe 10 | 425
Isaacsohn (1997) 163 | Atorvastatin 80 | NONE | 16
| Atorvastatin 40 | C-pol 20000 | 11
| Simvastatin 40 | C-pol 20000 | 10
| Mixed 40 | C-pol 20000 | 21
Kos Pharm (MA-14) 104 | Lovastatin 40 | NONE | 29
| Lovastatin 40 | Niacin (ER) 2500 | 23
| Lovastatin 20 | Niacin (ER) 2500 | 24
| Lovastatin 10 | Niacin (ER) 2500 | 30
| Lovastatin 10–40 | Niacin (ER) 2500 | 77
Kos Pharm (MA-06) 105 | Lovastatin 40 | NONE | 53
| Lovastatin 20 | Niacin (ER) 1000 | 40
| Lovastatin 40 | Niacin (ER) 2000 | 42
| Lovastatin 20–40 | Niacin (ER) 1000–2000 | 82
LDL-c - Lower dose statin plus nonstatin in combination compared with higher dose monotherapy using the same statin
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 51
| Rosuvastatin 10 | Fenofibrate 67 | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 5–10 | Fenofibrate 67 | 113
Feldman (2004) 47 | Simvastatin 40 | NONE | 248
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 10 | Ezetimibe 10 | 245
| Simvastatin 10–20 | Ezetimibe 10 | 451
LDL-c – high risk participants
Feldman (2004) 47 | Simvastatin 40 | NONE | 248
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 10 | Ezetimibe 10 | 245
| Simvastatin 10–40 | Ezetimibe 10 | 451
LDL-c - Lower dose statin plus nonstatin in combination compared with higher dose monotherapy using the same statin in high risk participants
Feldman (2004) 47 | Simvastatin 40 | NONE | 248
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 10 | Ezetimibe 10 | 245
| Simvastatin 10–20 | Ezetimibe 10 | 451
HDL-c
Feldman (2004) 47 | Simvastatin 20 | NONE | 248
| Simvastatin 10 | Ezetimibe 10 | 245
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 451
Insull (2004) 182 | Lovastatin 40 | NONE | 33
| Lovastatin 40 | Niacin (ER) 2500 | 32
| Lovastatin 10 | Niacin (ER) 2500 | 34
| Lovastatin 20 | Niacin (ER) 2500 | 34
| Lovastatin 10–40 | Niacin (ER) 2500 | 100
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 51
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 53
| Rosuvastatin 5–10 | Fenofibrate 67 | 113
Capuzzi (2003) 155 | Rosuvastatin 40 | NONE | 46
| Rosuvastatin 10 | Niacin (ER) 2000 | 78
| Rosuvastatin 40 | Niacin (ER) 1000 | 71
| Rosuvastatin 10–40 | Niacin (ER) 1000–2000 | 198
Davidson (2001) 185 | Lovastatin 10 | NONE | 26
| Lovastatin 10 | C-lam 2300 | 27
| Lovastatin 10 | C-lam 2300 | 23
| Lovastatin 10 | C-lam 2300 | 50
PMSG II (1993) 191 | Pravastatin 80 | NONE | 62
| Pravastatin 40 | NONE | 57
| Pravastatin 40 | NONE | 119
| Pravastatin 40 | C-amine 24000 | 61
Simons (1992) 173 | Simvastatin 40 | NONE | 22
| Simvastatin 40 | C-pol 5000 | 19
| Simvastatin 40 | C-pol 10000 | 20
| Simvastatin 40 | C-pol 5000–10000 | 39
McKenney (2007_2) 139 | Rosuvastatin 40 | NONE | 73
| Atorvastatin 40 | Niacin (ER) 2000 | 60
| Rosuvastatin 20 | Niacin (ER) 1000 | 65
| Mixed 20–40 | Niacin (ER) 1000–2000 | 125
Constance (2007) 194 | Atorvastatin 20 | NONE | 218
| Simvastatin 40 | Ezetimibe 10 | 220
| Simvastatin 20 | Ezetimibe 10 | 219
| Simvastatin 20–40 | Ezetimibe 10 | 439
Isaacsohn (1997) 163 | Atorvastatin 80 | NONE | 16
| Simvastatin 40 | C-pol 20000 | 10
| Atorvastatin 40 | C-pol 20000 | 11
| Mixed 40 | C-pol 20000 | 21
Kos Pharm (MA-14) 104 | Lovastatin 40 | NONE | 29
| Lovastatin 10 | Niacin (ER) 2500 | 30
| Lovastatin 20 | Niacin (ER) 2500 | 24
| Lovastatin 40 | Niacin (ER) 2500 | 23
| Lovastatin 10–40 | Niacin (ER) 2500 | 77
Kos Pharm (MA-06) 105 | Lovastatin 40 | NONE | 53
| Lovastatin 20 | Niacin (ER) 1000 | 40
| Lovastatin 40 | Niacin (ER) 2000 | 42
| Lovastatin 40 | Niacin (ER) 1000–2000 | 82
HDL-c - Lower dose statin plus nonstatin in combination compared with higher dose monotherapy using the same statin
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 51
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 53
| Rosuvastatin 5–10 | Fenofibrate 67 | 113
HDL-c – high risk participants
Goldberg (2006) 144 | Atorvastatin 10 | NONE | 237
| Atorvastatin 20 | NONE | 240
| Atorvastatin 40 | NONE | 241
| Atorvastatin 10–40 | NONE | 718
| Simvastatin 20 | Ezetimibe 10 | 238
| Simvastatin 40 | Ezetimibe 10 | 242
| Simvastatin 20–40 | Ezetimibe 10 | 480
HDL-c – participants with diabetes mellitus
Goldberg (2006) 144 | Atorvastatin 10 | NONE | 237
| Atorvastatin 20 | NONE | 240
| Atorvastatin 40 | NONE | 241
| Atorvastatin 10–40 | NONE | 718
| Simvastatin 20 | Ezetimibe 10 | 238
| Simvastatin 40 | Ezetimibe 10 | 242
| Simvastatin 20–40 | Ezetimibe 10 | 480
Total cholesterol: HDL-c ratio
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 51
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 53
| Rosuvastatin 5–40 | Fenofibrate 67 | 113
McKenney (2007_2) 139 | Rosuvastatin 40 | NONE | 73
| Atorvastatin 40 | Niacin (ER) 2000 | 60
| Rosuvastatin 20 | Niacin (ER) 1000 | 65
| Mixed 20–40 | Niacin (ER) 1000–2000 | 125
Constance (2007) 194 | Atorvastatin 20 | NONE | 218
| Simvastatin 40 | Ezetimibe 10 | 220
| Simvastatin 20 | Ezetimibe 10 | 219
| Simvastatin 20–40 | Ezetimibe 10 | 439
Goldberg (2006) 144 | Atorvastatin 10 | NONE | 237
| Atorvastatin 20 | NONE | 240
| Atorvastatin 40 | NONE | 241
| Atorvastatin 10–40 | NONE | 718
| Simvastatin 20 | Ezetimibe 10 | 238
| Simvastatin 40 | Ezetimibe 10 | 242
| Simvastatin 20–40 | Ezetimibe 10 | 480
Total cholesterol: HDL-c ratio – high risk participants
Goldberg (2006) 144 | Atorvastatin 10 | NONE | 237
| Atorvastatin 20 | NONE | 240
| Atorvastatin 40 | NONE | 241
| Atorvastatin 10–40 | NONE | 718
| Simvastatin 20 | Ezetimibe 10 | 238
| Simvastatin 40 | Ezetimibe 10 | 242
| Simvastatin 20–40 | Ezetimibe 10 | 480
Total cholesterol: HDL-c ratio – participants with diabetes mellitus
Goldberg (2006) 144 | Atorvastatin 10 | NONE | 237
| Atorvastatin 20 | NONE | 240
| Atorvastatin 40 | NONE | 241
| Atorvastatin 10–40 | NONE | 718
| Simvastatin 20 | Ezetimibe 10 | 238
| Simvastatin 40 | Ezetimibe 10 | 242
| Simvastatin 20–40 | Ezetimibe 10 | 480

Abbreviations: C-amine = colestyramine, C-lam = colesevelam, C-pol = colesipol, ER = extended release (niacin)

Table E-3

Within-trial, within-treatment pooling of multiple treatment group data for adverse events and treatment adherence

Outcome / Trial | Statin Dose (mg/day) | Non-statin drug Dose (mg/day) | Number of participants
Cancer
Kos Pharm (MA-06) 105 | Lovastatin 40 | NONE | 61
| Lovastatin 20 | Niacin (ER) 1000 | 57
| Lovastatin 40 | Niacin (ER) 2000 | 57
| Lovastatin 20–40 | Niacin (ER) 1000–2000 | 114
CPK above 10 times the upper limit of normal
Feldman (2004) 47 | Simvastatin 40 | NONE | 248
| Simvastatin 10 | Ezetimibe 10 | 245
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 451
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 55
| Rosuvastatin 5–10 | Fenofibrate 67 | 115
Capuzzi (2003) 155 | Rosuvastatin 40 | NONE | 46
| Rosuvastatin 10 | Niacin (ER) 2000 | 80
| Rosuvastatin 40 | Niacin (ER) 1000 | 72
| Rosuvastatin 10–40 | Niacin (ER) 1000–2000 | 152
McKenney (2007) 139 | Rosuvastatin 40 | NONE | 73
| Simvastatin 40 | Ezetimibe 10 | 72
| Rosuvastatin 40 | NONE | 73
| Rosuvastatin 20 | Niacin (ER) 1000 | 65
| Atorvastatin 40 | Niacin (ER) 2000 | 60
| Mixed 20–40 | Niacin (ER) 1000–2000 | 125
Kos Pharm (MA-14) 104 | Lovastatin 40 | NONE | 33
| Lovastatin 10 | Niacin (ER) 2500 | 34
| Lovastatin 20 | Niacin (ER) 2500 | 34
| Lovastatin 40 | Niacin (ER) 2500 | 32
| Lovastatin 10–40 | Niacin (ER) 2500 | 100
Kos Pharm (MA-06) 105 | Lovastatin 40 | NONE | 61
| Lovastatin 20 | Niacin (ER) 1000 | 57
| Lovastatin 40 | Niacin (ER) 2000 | 57
| Lovastatin 40 | Niacin (ER) 1000–2000 | 114
CPK above 10 times the upper limit of normal - Lower dose statin plus nonstatin in combination compared with higher dose monotherapy using the same statin
Feldman (2004) 47 | Simvastatin 40 | NONE | 248
| Simvastatin 10 | Ezetimibe 10 | 245
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 451
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 55
| Rosuvastatin 5–10 | Fenofibrate 67 | 115
Elevated serum AST, ALT or hepatitis
Feldman (2004) 47 | Simvastatin 40 | NONE | 248
| Simvastatin 10 | Ezetimibe 10 | 245
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 451
Insull (2004) 182 | Lovastatin 40 | NONE | 33
| Lovastatin 10 | Niacin (ER) 2500 | 34
| Lovastatin 20 | Niacin (ER) 2500 | 34
| Lovastatin 40 | Niacin (ER) 2500 | 32
| Lovastatin 10–40 | Niacin (ER) 2500 | 100
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 55
| Rosuvastatin 5–10 | Fenofibrate 67 | 115
Capuzzi (2003) 155 | Rosuvastatin 40 | NONE | 46
| Rosuvastatin 10 | Niacin (ER) 2000 | 80
| Rosuvastatin 40 | Niacin (ER) 1000 | 72
| Rosuvastatin 10–40 | Niacin (ER) 1000–2000 | 152
Hunninghake (2003) 128 | Lovastatin 40 | NONE | 61
| Lovastatin 20 | Niacin (ER) 1000 | 57
| Lovastatin 40 | Niacin (ER) 2000 | 57
| Lovastatin 20–40 | Niacin (ER) 1000–2000 | 114
Athyros (2001) 50 | Atorvastatin 20 | NONE | 131
| Pravastatin 20 | Gemfibrozil 1200 | 133
| Simvastatin 20 | Gemfibrozil 1200 | 129
| Mixed 20 | Gemfibrozil 1200 | 262
Davidson (2001) 185 | Lovastatin 10 | NONE | 26
| Lovastatin 10 | C-lam 2300 | 23
| Lovastatin 10 | C-lam 2300 | 27
| Lovastatin 10 | C-lam 300 | 50
Constance (2007) 194 | Atorvastatin 20 | NONE | 219
| Simvastatin 20 | Ezetimibe 10 | 220
| Simvastatin 40 | Ezetimibe 10 | 222
| Simvastatin 20–40 | Ezetimibe 10 | 442
Kos Pharm (MA-14) 104 | Lovastatin 40 | NONE | 33
| Lovastatin 10 | Niacin (ER) 2500 | 34
| Lovastatin 20 | Niacin (ER) 2500 | 34
| Lovastatin 40 | Niacin (ER) 2500 | 32
| Lovastatin 10–40 | Niacin (ER) 2500 | 100
Ballantyne (2008_a) 150 | Simvastatin 20 | NONE | 114
| Simvastatin 20 | Niacin (ER) 1000 | 123
| Simvastatin 20 | Niacin (ER) 2000 | 64
| Simvastatin 20 | Niacin (ER) 1000–2000 | 187
Ballantyne (2008_b) 171 | Simvastatin 20 | NONE | 119
| Simvastatin 20 | Niacin (ER) 1000 | 116
| Simvastatin 20 | Niacin (ER) 2000 | 100
| Simvastatin 20 | Niacin (ER) 1000–2000 | 216
Elevated serum AST, ALT or hepatitis - Lower dose statin plus nonstatin in combination compared with higher dose monotherapy using the same statin
Feldman (2004) 47 | Simvastatin 40 | NONE | 248
| Simvastatin 10 | Ezetimibe 10 | 245
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 451
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 55
| Rosuvastatin 5–10 | Fenofibrate 67 | 115
Myalgia
Kosoglou (2004-b) 181 | Lovastatin 20 | NONE | 8
| Lovastatin 20 | Ezetimibe 10 | 8
| Lovastatin 40 | Ezetimibe 10 | 7
| Lovastatin 20–40 | Ezetimibe 10 | 15
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 55
| Rosuvastatin 5–10 | Fenofibrate 67 | 115
Capuzzi (2003) 155 | Rosuvastatin 40 | NONE | 46
| Rosuvastatin 10 | Niacin (ER) 2000 | 80
| Rosuvastatin 40 | Niacin (ER) 1000 | 72
| Rosuvastatin 10–40 | Niacin (ER) 1000–2000 | 152
Athyros (2001) 50 | Atorvastatin 20 | NONE | 131
| Simvastatin 20 | Gemfibrozil 1200 | 129
| Pravastatin 20 | Gemfibrozil 1200 | 133
| Mixed 20 | Gemfibrozil 1200 | 262
Davidson (2001) 185 | Lovastatin 10 | NONE | 26
| Lovastatin 10 | C-lam 2300 | 27
| Lovastatin 10 | C-lam 2300 | 23
| Lovastatin 10 | C-lam 2300 | 50
Myalgia - Lower dose statin plus nonstatin in combination compared with higher dose monotherapy using the same statin
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 55
| Rosuvastatin 5–10 | Fenofibrate 67 | 115
Rhabdomyolysis Feldman (2004) 47 | Simvastatin 40 | NONE | 253
| Simvastatin 10 | Ezetimibe 10 | 251
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 457
Kos Pharm (MA-14) 104 | Lovastatin 40 | NONE | 33
| Lovastatin 10 | Niacin (ER) 2500 | 34
| Lovastatin 20 | Niacin (ER) 2500 | 34
| Lovastatin 40 | Niacin (ER) 2500 | 32
| Lovastatin 10–40 | Niacin (ER) 2500 | 100
Ballantyne (2008_a) 150 | Simvastatin 20 | NONE | 114
| Simvastatin 20 | Niacin (ER) 1000 | 123
| Simvastatin 20 | Niacin (ER) 2000 | 64
| Simvastatin 20 | Niacin (ER) 1000–2000 | 187
Ballantyne (2008_b) 171 | Simvastatin 20 | NONE | 119
| Simvastatin 20 | Niacin (ER) 1000 | 116
| Simvastatin 20 | Niacin (ER) 2000 | 100
| Simvastatin 20 | Niacin (ER) 1000–2000 | 216
Rhabdomyolysis - Lower dose statin plus nonstatin in combination compared with higher dose monotherapy using the same statin
Feldman (2004) 47 | Simvastatin 40 | NONE | 253
| Simvastatin 10 | Ezetimibe 10 | 251
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 457
Serious adverse events
Feldman (2004) 47 | Simvastatin 40 | NONE | 253
| Simvastatin 10 | Ezetimibe 10 | 251
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 457
Kos Pharm (MA-14) 104 | Lovastatin 40 | NONE | 33
| Lovastatin 10 | Niacin (ER) 2500 | 34
| Lovastatin 20 | Niacin (ER) 2500 | 34
| Lovastatin 40 | Niacin (ER) 2500 | 32
| Lovastatin 10–40 | Niacin (ER) 2500 | 100
Ballantyne (2008_a) 150 | Simvastatin 20 | NONE | 114
| Simvastatin 20 | Niacin (ER) 1000 | 123
| Simvastatin 20 | Niacin (ER) 2000 | 64
| Simvastatin 20 | Niacin (ER) 1000–2000 | 187
Ballantyne (2008_b) 171 | Simvastatin 20 | NONE | 119
| Simvastatin 20 | Niacin (ER) 1000 | 116
| Simvastatin 20 | Niacin (ER) 2000 | 100
| Simvastatin 20 | Niacin (ER) 1000–2000 | 216
Serious adverse events - Lower dose statin plus nonstatin in combination compared with higher dose monotherapy using the same statin
Feldman (2004) | Simvastatin 40 | NONE | 253
| Simvastatin 10 | Ezetimibe 10 | 251
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 457
Total adverse events
Feldman (2004) 47 | Simvastatin 40 | NONE | 253
| Simvastatin 10 | Ezetimibe 10 | 251
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 457
Insull (2004) 182 | Lovastatin 40 | NONE | 33
| Lovastatin 10 | Niacin (ER) 2500 | 34
| Lovastatin 20 | Niacin (ER) 2500 | 34
| Lovastatin 40 | Niacin (ER) 2500 | 32
| Lovastatin 10–40 | Niacin (ER) 2500 | 100
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 55
| Rosuvastatin 5–10 | Fenofibrate 67 | 115
Capuzzi (2003) 155 | Rosuvastatin 40 | NONE | 46
| Rosuvastatin 10 | Niacin (ER) 2000 | 80
| Rosuvastatin 40 | Niacin (ER) 1000 | 72
| Rosuvastatin 10–40 | Niacin (ER) 1000–2000 | 152
Johansson (1995) 137 | Simvastatin 40 | NONE | 26
| Simvastatin 20 | C-pol 5000 | 29
| Simvastatin 20 | C-pol 10000 | 28
| Simvastatin 20 | C-pol 5000–10000 | 57
Kos Pharm (MA-14) 104 | Lovastatin 40 | NONE | 33
| Lovastatin 10 | Niacin (ER) 2500 | 34
| Lovastatin 20 | Niacin (ER) 2500 | 34
| Lovastatin 40 | Niacin (ER) 2500 | 32
| Lovastatin 10–40 | Niacin (ER) 2500 | 100
Kos Pharm (MA-06) 105 | Lovastatin 40 | NONE | 61
| Lovastatin 20 | Niacin (ER) 1000 | 57
| Lovastatin 40 | Niacin (ER) 2000 | 57
| Lovastatin 20–40 | Niacin (ER) 1000–2000 | 114
Ballantyne (2008_a) 150 | Simvastatin 20 | NONE | 114
| Simvastatin 20 | Niacin (ER) 1000 | 123
| Simvastatin 20 | Niacin (ER) 2000 | 64
| Simvastatin 20 | Niacin (ER) 1000–2000 | 187
Ballantyne (2008_b) 171 | Simvastatin 20 | NONE | 119
| Simvastatin 20 | Niacin (ER) 1000 | 116
| Simvastatin 20 | Niacin (ER) 2000 | 100
| Simvastatin 20 | Niacin (ER) 1000–2000 | 216
Total adverse events - Lower dose statin plus nonstatin in combination compared with higher dose monotherapy using the same statin
Feldman (2004) 47 | Simvastatin 40 | NONE | 253
| Simvastatin 10 | Ezetimibe 10 | 251
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 457
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 55
| Rosuvastatin 5–10 | Fenofibrate 67 | 115
Johansson (1995) 137 | Simvastatin 40 | NONE | 26
| Simvastatin 20 | C-pol 5000 | 29
| Simvastatin 20 | C-pol 10000 | 28
| Simvastatin 20 | C-pol 5000–10000 | 57
Treatment Adherence Capuzzi (2003) 155 | Rosuvastatin 40 | NONE | 46
| Rosuvastatin 10 | Niacin (ER) 2000 | 80
| Rosuvastatin 40 | Niacin (ER) 1000 | 72
| Rosuvastatin 10–40 | Niacin (ER) 1000–2000 | 152
Hunninghake (2001) 133 | Atorvastatin 10 | NONE | 19
| Atorvastatin 80 | NONE | 20
| Atorvastatin 10–80 | NONE | 39
| Atorvastatin 10 | C-lam 3800 | 19
Eriksson (1998) 190 | Pravastatin 20 | NONE | 403
| Pravastatin 40 | NONE | 409
| Pravastatin 20–40 | NONE | 812
| Pravastatin 20 | chlestyramine 8000 | 261
Johansson (1995) 137 | Simvastatin 40 | NONE | 26
| Simvastatin 20 | C-pol 5000 | 29
| Simvastatin 20 | C-pol 10000 | 28
| Simvastatin 20 | C-pol 5000–10000 | 57
McKenney (2007) 139 | Rosuvastatin 40 | NONE | 73
| Simvastatin 40 | Ezetimibe 10 | 72
| Rosuvastatin 40 | NONE | 73
| Rosuvastatin 20 | Niacin (ER) 1000 | 65
| Atorvastatin 40 | Niacin (ER) 2000 | 60
| Mixed 20–40 | Niacin (ER) 1000–2000 | 125
Treatment Adherence - Lower dose statin plus nonstatin in combination compared with higher dose monotherapy using the same statin
Johansson (1995) 137 | Simvastatin 40 | NONE | 26
| Simvastatin 20 | C-pol 5000 | 29
| Simvastatin 20 | C-pol 10000 | 28
| Simvastatin 20 | C-pol 5000–10000 | 57
Withdrawal due to adverse events
Feldman (2004) 47 | Simvastatin 40 | NONE | 253
| Simvastatin 10 | Ezetimibe 10 | 251
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 457
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 55
| Rosuvastatin 5–10 | Fenofibrate 67 | 115
Gagne (2002) 132 | Mixed 80 | NONE | 17
| Mixed 40 | Ezetimibe 10 | 16
| Mixed 80 | Ezetimibe 10 | 17
| Mixed 40–80 | Ezetimibe 10 | 33
Athyros (2001) 50 | Atorvastatin 20 | NONE | 134
| Simvastatin 20 | Gemfibrozil 1200 | 136
| Pravastatin 20 | Gemfibrozil 1200 | 135
| Mixed 20 | Gemfibrozil 1200 | 271
Hunninghake (2001) 133 | Atorvastatin 10 | NONE | 19
| Atorvastatin 80 | NONE | 20
| Atorvastatin 10–80 | NONE | 39
| Atorvastatin 10 | C-lam 3800 | 19
Davidson (2001) 185 | Lovastatin 10 | NONE | 26
| Lovastatin 10 | C-lam 2300 | 27
| Lovastatin 10 | C-lam 2300 | 23
| Lovastatin 10 | C-lam 2300 | 50
PMSG II (1993) 191 | Pravastatin 40 | NONE | 63
| Pravastatin 80 | NONE | 63
| Pravastatin 40–80 | NONE | 126
| Pravastatin 40 | chlestyramine 24000 | 64
Constance (2007) 194 | Atorvastatin 20 | NONE | 219
| Simvastatin 20 | Ezetimibe 10 | 220
| Simvastatin 40 | Ezetimibe 10 | 222
| Simvastatin 20–40 | Ezetimibe 10 | 442
Kos Pharm (MA-14) 104 | Lovastatin 40 | NONE | 33
| Lovastatin 10 | Niacin (ER) 2500 | 34
| Lovastatin 20 | Niacin (ER) 2500 | 34
| Lovastatin 40 | Niacin (ER) 2500 | 32
| Lovastatin 10–40 | Niacin (ER) 2500 | 100
Kos Pharm (MA-06) 105 | Lovastatin 40 | NONE | 61
| Lovastatin 20 | Niacin (ER) 1000 | 57
| Lovastatin 40 | Niacin (ER) 2000 | 57
| Lovastatin 20–40 | Niacin (ER) 1000–2000 | 114
Ballantyne (2008_a) 150 | Simvastatin 20 | NONE | 114
| Simvastatin 20 | Niacin (ER) 1000 | 123
| Simvastatin 20 | Niacin (ER) 2000 | 64
| Simvastatin 20 | Niacin (ER) 1000–2000 | 187
Ballantyne (2008_b) 171 | Simvastatin 20 | NONE | 119
| Simvastatin 20 | Niacin (ER) 1000 | 116
| Simvastatin 20 | Niacin (ER) 2000 | 100
| Simvastatin 20 | Niacin (ER) 1000–2000 | 216
Withdrawal due to adverse events - Lower dose statin plus nonstatin in combination compared with higher dose monotherapy using the same statin
Feldman (2004) 47 | Simvastatin 40 | NONE | 253
| Simvastatin 10 | Ezetimibe 10 | 251
| Simvastatin 20 | Ezetimibe 10 | 109
| Simvastatin 40 | Ezetimibe 10 | 97
| Simvastatin 10–40 | Ezetimibe 10 | 457
Durrington (2004) 125 | Rosuvastatin 40 | NONE | 53
| Rosuvastatin 5 | Fenofibrate 67 | 60
| Rosuvastatin 10 | Fenofibrate 67 | 55
| Rosuvastatin 5–10 | Fenofibrate 67 | 115

Abbreviations: C-amine = colestyramine, C-lam = colesevelam, C-pol = colesipol, ER = extended release (niacin)