# Appendix D Planned Analyses

Outcome | Sensitivity analysis | Data | Any statin | Ator | Sim | Ros | Prava | Fluv | Lov
| | | | Lower dose statin in combination versus higher dose monotherapy Fixed dose or fixed titration All dosing schedules, including conditional titration
All-cause mortality | | n/N | A, R, S | A, R, S | A, R, S | A, R, S | R, S | R, S | R, S
All-cause mortality | AAC | n/N | A, R, S | A, R, S | A, R, S | A, R, S | R, S | R, S | R, S
Vascular death | | n/N | A, R, S | A, R, S | A, R, S | A, R, S | R, S | R, S | R, S
Vascular death | AAC | n/N | A, R, S | A, R, S | A, R, S | A, R, S | R, S | R, S | R, S
Fatal myocardial infarction | | n/N | A | A | A | A
Nonfatal myocardial infarction | | n/N | A | A | A | A
Any (STEMI and/or non-STEMI) or unspecified myocardial infarction | | n/N | A | A | A | A
Any cerebrovascular event | | n/N | A | A | A | A
Hemorrhagic stroke | | n/N | A | A | A | A
Ischemic stroke | | n/N | A | A | A | A
TIA | | n/N | A | A | A | A
Any or unspecified stroke | | n/N | A | A | A | A
Acute coronary syndrome | | n/N | A | A | A | A
Carotid endarterectomy | | n/N | A | A | A | A
Percutaneous coronary intervention | | n/N | A | A | A | A
CABG | | n/N | A | A | A | A
Revascularization procedures | | n/N | A | A | A | A
For all clinical outcomes, conduct additional analyses on trials of followup duration of 24 weeks or more
Treatment Adherence | | n/N | A | A | A | A
Participants with at least one adverse event | | n/N | A | A | | A
Serious adverse events | | n/N | A | A | A | A
Withdrawal due to adverse events | | n/N | A | A | A | A
Cancer | | n/N | A | A | A | A
Elevated AST and/or ALT > 3 times ULN and/or hepatitis | | n/N | A | A | A | A
Myalgia | | n/N | A | A | A | A
CPK > 10 times ULN | | n/N | A | A | A | A
Rhabdomyolysis (investigator defined) | | n/N | A | A | A | A
For serious adverse events, conduct additional analyses on trials with followup duration of 24 weeks or more
Participants attaining ATP III LDL-c targets | | n/N | A, R, S | A, R, S | A, R, S | A, R, S | R, S | R, S | R, S
LDL-c
| | Mean % change from baseline OR change score | A, R, S | A, R, S | A, R, S | A, R, S | R, S | R, S | R, S
HDL-c
| | Mean % change from baseline OR change score | A, R, S | A, R, S | A, R, S | A, R, S | R, S | R, S | R, S
TC:HDL-c ratio
| | Mean % change from baseline OR change score | A, R, S | A, R, S | A, R, S | A, R, S | R, S | R, S | R, S
Non-HDL-c
| | Mean % change from baseline OR change score | S (diabetes mellitus subgroup only) | S (diabetes mellitus subgroup only) | S (diabetes mellitus subgroup only) | S (diabetes mellitus subgroup only) | S (diabetes mellitus subgroup only) | S (diabetes mellitus subgroup only) | S (diabetes mellitus subgroup only)
Triglycerides
| | Mean % change from baseline OR change score | S (diabetes mellitus subgroup only) | S (diabetes mellitus subgroup only) | S (diabetes mellitus subgroup only) | S (diabetes mellitus subgroup only) | S (diabetes mellitus subgroup only) | S (diabetes mellitus subgroup only) | S (diabetes mellitus subgroup only)
Carotid artery
| | IMT (mm) | A | A | A | A
| | plaque area | A | A | A | A
| | plaque volume | A | A | A | A
| | %stenosis | A | A | A | A
| | calcif’n | A | A | A | A
Coronary artery
| | IMT (mm) | A | A | A | A
| | plaque area | A | A | A
| | Plaque volume | A | A | A | A
| | %stenosis | A | A | A | A
| | calcif’n | A | A | A | A

Abbreviations: A = analyses of all study populations, AAC = adequate allocation concealment; calcif’n = calcification, Any statin = Any statin (including mixed) + nonstatin drug, versus any statin (including mixed) of any dose, Ator = Atorvastatin 5-20 mg/day + nonstatin drug, versus Atorvastatin 40-80 mg/day, CABG = coronary arterial bypass graft, Fluv = Fluvastatin 5-40 mg/day + ezetimibe 10 mg/day, versus Fluvastatin 80 mg/day, IMT = intima-media thickness, Lov = Lovastatin 5-40 mg/day + another hypolipidemic versus Lovastatin 80 mg/day, n = number with particular outcome in statistical analysis, N = total number in group or trial, Prava = Pravastatin 5-40 mg/day + another hypolipidemic drug, versus Pravastatin 80, R = populations requiring intensive lipid-lowering therapy, Ros = Rosuvastatin 5-10 mg/day + nonstatin drug versus Rosuvastatin 20-40 mg/day, S = pre-specified subgroups, Sim = Simvastatin 5-20 mg/day + nonstatin drug, versus Simvastatin 40-80 mg/day, TIA = transient ischemic attack