# Appendix B Excluded Studies

## Excluded Studies - FullText Relevance

### Do Not Directly Address the Key Questions

Aberg JA, Zackin RA, Brobst SW, et al. A randomized trial of the efficacy and safety of fenofibrate versus pravastatin in HIV-infected subjects with lipid abnormalities: AIDS Clinical Trials Group Study 5087. AIDS Research & Human Retroviruses 2005;21(9):757–767.

ACCORD Study Group. Action to Control Cardiovascular Risk in Diabetes (ACCORD) trial: design and methods. Am J Cardiol 2007;99(12A):21i–33i.

Adams RJ, Albers G, Alberts MJ, et al. Update to the AHA/ASA recommendations for the prevention of stroke in patients with stroke and transient ischemic attack. Stroke 2008; 39(5):1647–1652.

Afilalo J, Duque G, Steele R, et al. Statins for secondary prevention in elderly patients: a hierarchical bayesian meta-analysis [see comment]. J Am Coll Cardiol 2008; 51(1):37–45.

Akoglu H, Yilmaz R, Kirkpantur A, et al. Combined organ failure with combination antihyperlipidemic treatment: a case of hepatic injury and acute renal failure. Ann Pharmacother 2007;41(1):143–147.

Alaupovic P, Fesmire JD, Hunnighake D, et al. The effect of aggressive and moderate lowering of LDL-cholesterol and low dose anticoagulation on plasma lipids, apolipoproteins and lipoprotein families in post coronary artery bypass graft trial. Atherosclerosis 1999;146(2):369–379.

Alexandridis G, Pappas GA, Elisaf MS. Rhabdomyolysis due to combination therapy with cerivastatin and gemfibrozil [see comment]. Am J Med 2000;109(3):261–262.

Aligeti VR, Gandhi M, Braden R, et al. Effect of combination lipid-modifying therapy on the triglyceride lowering effect of fish oil. Am J Med Sci 2007;333(3):168–172.

Al-Olah Y H, Carr-Lopez S M. Rhabdomyolysis secondary to the concomitant use of simvastatin and gemfibrozil. Saudi Pharm J 2002;10(1–2):65–69.

Amarenco P, Lavallee PC, Mazighi M, et al. The role of statins in the prevention of stroke. Archives of Medical Science 2007; 3(4 SUPPL. A):S109–S114.

Andrade SE, Graham DJ, Staffa JA, et al. Health plan administrative databases can efficiently identify serious myopathy and rhabdomyolysis. J Clin Epidemiol 2005;58(2):171–174.

Anonymous. Case report: Combination therapy for metabolic syndrome. Cardiol Rev 2005;22(1):42.

Anonymous. Case report: Improved lipid levels with niacin-ER/lovastatin. Cardiol Rev 2003;20(11):38.

Anonymous. Combination therapy for mixed dyslipidemia in an elderly man with diabetes. Cardiol Rev 2007;24(4):28.

Anonymous. Myopathy and rhabdomyolysis with lovastatin taken with gemfibrozil [comment]. JAMA 1990;264(23):2991–2992.

Anonymous. Study of Heart and Renal Protection (SHARP): Final Protocol Version 4: 14 July 2003. National Research Register, UK [www 2004;nrr.nhs.uk/]. 2004.

Arambepola C, Farmer AJ, Perera R, et al. Statin treatment for children and adolescents with heterozygous familial hypercholesterolaemia: a systematic review and meta-analysis [review] [60 refs]. Atherosclerosis 2007;195(2):339–347.

Armstrong EP, Zachry WM, Malone DC. Cost-effectiveness analysis of simvastatin and lovastatin/extended- release niacin to achieve LDL and HDL goal using NHANES data.[see comment]. Journal of Managed Care Pharmacy 2004;10(3):251–258.

Aronow WS. Treatment of high-risk older adults with lipid-lowering drug therapy. Geriatrics and Aging 2007;10(3):167–173.

Aronow WS. Treatment of high-risk older persons with lipid-lowering drug therapy [review] [34 refs]. Am J Ther 2008;15(2):102–107.

Arshad A, Mandava A, Kamath G, et al. Sudden cardiac death and the role of medical therapy [review] [146 refs]. Prog Cardiovasc Dis 2008; 50(6):420–438.

Asztalos B F, Batista M, Horvath KV, et al. Change in alpha1 HDL concentration predicts progression in coronary artery stenosis. Arterioscler Thromb Vasc Biol 2003;23(5):847–852.

Athyros VG, Papageorgiou AA, Hatzikonstandinou HA, et al. Safety and efficacy of long-term statin-fibrate combinations in patients with refractory familial combined hyperlipidemia. Am J Cardiol 1997;80(5):608–613.

Athyros VG, Papageorgiou AA, Kontopoulos A G. Statin-fibrate combinations in patients with combined hyperlipidemia. Atherosclerosis 2001;155(1):263–264.

Athyros V, Papageorgiou A, Athyrou V, et al. Long term safety and efficacy of atorvastatin versus four statin-fibrate combinations on lipid profile and plasma fibrinogen in patients with familial combined hyperlipidemia. Atheroscler Suppl 1999;144(1):28.

Athyros VG, Kakafika AI, Koragiannis A, et al. Effects of simvastatin alone versus fenofibrate alone versus simvastatin plus fenofibrate on lipoprotein subparticle profiles in patients with diabetes mellitus and mixed dyslipidemia. Am J Cardiol 2008;101(11):1679–1680.

Athyros VG, Tziomalos K, Kakafika AI, et al. Effectiveness of ezetimibe alone or in combination with twice a week Atorvastatin (10 mg) for statin intolerant high-risk patients. Am J Cardiol 2008;101(4):483–485.

Aung PP, Maxwell HG, Jepson RG, et al. Lipid-lowering for peripheral arterial disease of the lower limb[update of Cochrane Database Syst Rev. 2000;(2):CD000123; PMID: 10796489] [review] [91 refs]. Cochrane Database Syst Rev 2007;(4):CD000123.

Bach LA, Cooper ME, O’Brien RC, et al. The use of simvastatin, an HMG CoA reductase inhibitor, in older patients with hypercholesterolemia and atherosclerosis. J Am Geriatr Soc 1990;38(1):10–14.

Backman JT, Kyrklund C, Kivisto KT, et al. Plasma concentrations of active simvastatin acid are increased by gemfibrozil. Clinical Pharmacology & Therapeutics 2000;68(2):122–129.

Badawy O, Wierzbicki AS, Hilton R. Combination fibrate-statin therapy for the treatment of severe hypertriglyceridaemia in renal disease. Int J Clin Pract 2003;57(3):249–251.

Badger SA, Soong CV, Lee B, et al. Prescribing practice of general practitioners in Northern Ireland for peripheral arterial disease. Angiology 2008; 59(1):57–63.

Baldovi F, Galindo MJ, Alcacer F, et al. Acute renal failure and lipid-lowering therapy. Nutr Metab Disord HIV Infect 2004;3(2):437–439.

Ballantyne CM, Radovancevic B, Farmer JA, et al. Hyperlipidemia after heart transplantation: report of a 6-year experience, with treatment recommendations. J Am Coll Cardiol 1992;19(6):1315–1321.

Bard JM, Dallongeville J, Hagen E, et al. Comparison of the effect of fluvastatin, an hydroxymethyl glutaryl coenzyme A reductase inhibitor, and cholestyramine, a bile acid sequestrant, on lipoprotein particles defined by apolipoprotein composition. Metabolism: Clinical & Experimental 1995;44(11):1447–1454.

Barkowski RS, Frishman WH. HDL metabolism and CETP inhibition. Cardiol Rev 2008; 16(3):154–162.

Bar-On P, Crews L, Koob AO, et al. Statins reduce neuronal alpha-synuclein aggregation in in vitro models of Parkinson’s disease. J Neurochem 2008;105(5):1656–1667.

Barter PJ, O’Brien RC. Achievement of target plasma cholesterol levels in hypercholesterolaemic patients being treated in general practice. Atherosclerosis 2000;149(1):199–205.

Barter P. Reconsidering the value of fibrates: Lessons from the trials. British Journal of Diabetes & Vascular Disease 2003;3(3):162–167.

Bayes M, Rabasseda X, Prous JR. Gateways to clinical trials. Methods Find Exp Clin Pharmacol 2007;29(9):625–655.

Bays H, Lansing AM. Fish oil (omega-3 fatty acids) in treatment of hypertriglyceridemia. A practical approach for the primary care physician. J Ky Med Assoc 1994;92(3):105–108.

Bays H, McKenney J, Davidson M. Torcetrapib/atorvastatin combination therapy. Expert Review of Cardiovascular Therapy 2005;3(5):789–820.

Bays H. Safety of niacin and simvastatin combination therapy [review] [26 refs]. Am J Cardiol 2008;101(8A):3B–8B.

bdul-Ghaffar NU, el-Sonbaty MR. Pancreatitis and rhabdomyolysis associated with lovastatin-gemfibrozil therapy. J Clin Gastroenterol 1995;21(4):340–341.

Beggs P W, Clark DW, Williams SM, et al. A comparison of the use, effectiveness and safety of bezafibrate, gemfibrozil and simvastatin in normal clinical practice using the New Zealand Intensive Medicines Monitoring Programme (IMMP). Br J Clin Pharmacol 1999;47(1):99–104.

Benatar JR, Stewart RA. Is it time to stop treating dyslipidaemia with fibrates? [review] [23 refs]. N Z Med J 2007;120(1261):U2706.

Bennett MT, Johns KW, Bondy GP. Ezetimibe is effective when added to maximally tolerated lipid lowering therapy in patients with HIV. Lipids in Health & Disease 2007;615.

Berger GM, Marais AD, Seftel HC, et al. Treatment of hypercholesterolemia with the HMG CoA reductase inhibitor, simvastatin. Cardiovascular Drugs & Therapy 1989;3(2):219–227.

Bergman AJ, Murphy G, Burke J, et al. Simvastatin does not have a clinically significant pharmacokinetic interaction with fenofibrate in humans. J Clin Pharmacol 2004;44(9):1054–1062.

Bermingham RP, Whitsitt TB, Smart ML, et al. Rhabdomyolysis in a patient receiving the combination of cerivastatin and gemfibrozil. Am J Health Syst Pharm 2000;57(5):461–464.

Bertolotti M, Zambianchi L, Carulli L, et al. Influence of newly synthesized cholesterol on bile acid synthesis during chronic inhibition of bile acid absorption. J Gastroenterol Hepatol 2003;38(4):939–946.

Bilheimer DW, Grundy SM, Brown MS, et al. Mevinolin and colestipol stimulate receptor-mediated clearance of low density lipoprotein from plasma in familial hypercholeserolemia heterozygotes. 1983. Atheroscler Suppl 2004;5(3):61–65.

Bilheimer DW, Grundy SM, Brown MS, et al. Mevinolin and colestipol stimulate receptor-mediated clearance of low density lipoprotein from plasma in familial hypercholesterolemia heterozygotes. Proc Natl Acad Sci U S A 1983;80(13):4124–4128.

Bilz S, Wagner S, Schmitz M, et al. Effects of atorvastatin versus fenofibrate on apoB-100 and apoA-I kinetics in mixed hyperlipidemia. J Lipid Res 2004;45(1):174–185.

Birjmohun RS, Kastelein JJ, Poldermans D, et al. Safety and tolerability of prolonged-release nicotinic acid in statin-treated patients. Curr Med Res Opin 2007;23(7):1707–1713.

Bissonnette S, Habib R, Sampalis F, et al. Efficacy and tolerability of ezetimibe 10 mg/day coadministered with statins in patients with primary hypercholesterolemia who do not achieve target LDL-C while on statin monotherapy: A Canadian, multicentre, prospective study—the Ezetrol Add-On Study. Can J Cardiol 2006;22(12):1035–1044.

Black C, Jick H. Etiology and frequency of rhabdomyolysis. Pharmacotherapy 2002;22(12):1524–1526.

Blair SN, Capuzzi DM, Gottlieb SO, et al. Incremental reduction of serum total cholesterol and low-density lipoprotein cholesterol with the addition of plant stanol ester-containing spread to statin therapy. Am J Cardiol 2000;86(1):46–52.

Blom DJ, Byrnes P, Jones S, et al. Dysbetalipoproteinaemia—clinical and pathophysiological features. S Afr Med J 2002; Suid-Afrikaanse Tydskrif Vir Geneeskunde. 92(11):892–897.

Blum S, Milman U, Shapira C, et al. Dual therapy with statins and antioxidants is superior to statins alone in decreasing the risk of cardiovascular disease in a subgroup of middle-aged individuals with both diabetes mellitus and the haptoglobin 2-2 genotype. Arterioscler Thromb Vasc Biol 2008;28(3):e18–e20.

Bonnet F, Balestre E, Thiebaut R, et al. Fibrates or statins and lipid plasma levels in 245 patients treated with highly active antiretroviral therapy. Aquitaine Cohort, France, 1999–2001. HIV Med 2004;5(3):133–139.

Bonovas S, Filioussi K, Sitaras NM. Statin use and the risk of prostate cancer: A metaanalysis of 6 randomized clinical trials and 13 observational studies. Int J Cancer 2008; 123(4):899–904.

Bonovas S, Filioussi K, Tsantes A, et al. Use of statins and risk of haematological malignancies: a meta-analysis of six randomized clinical trials and eight observational studies [review] [47 refs]. Br J Clin Pharmacol 2007; 64(3):255–262.

Bouknight P, Mackler L, Heffington M. FPIN’s clinical inquiries. Best alternatives to statins for treating hyperlipidemia. [Review] [10 refs]. Am Fam Physician 2007; 76(7):1027–1029.

Bozbas H, Altin C, Yildirir A et al. Lipid profiles of patients with a transplanted heart before and after the operation. Transplant Proc 2008; 40(1):263–266.

Bright J. American Heart Association—Scientific Sessions 2007. Part 1. Idrugs 2008; 11(1):16–18.

Brophy JM, Costa V. Statin wars following coronary revascularization—evidence-based clinical practice? Can J Cardiol 2006;22(1):54–58.

Brown BG, Bardsley J, Poulin D, et al. Moderate dose, three-drug therapy with niacin, lovastatin, and colestipol to reduce low-density lipoprotein cholesterol <100 mg/dl in patients with hyperlipidemia and coronary artery disease. Am J Cardiol 1997;80(2):111–115.

Brown BG, Zambon A, Poulin D, et al. Use of niacin, statins, and resins in patients with combined hyperlipidemia [review] [20 refs]. Am J Cardiol 1998;81(4A):52B–59B.

Brown B G, Zhao X Q, Chait A, et al. Simvastatin and niacin, antioxidant vitamins, or the combination for the prevention of coronary disease [see comment][summary for patients in Curr Cardiol Rep. 2002 Nov;4(6):486; PMID: 12379170]. N Engl J Med 2001;345(22):1583–1592.

Brown BG, Zhao X-Q, Chait A, et al. Simvastatin and niacin, antioxidant vitamins, or the combination for the prevention of coronary disease. N Engl J Med 2001;345(22):1583–1592.

Brown BG, Zhao X-Q, Cheung MC. Should both HDL-C and LDL-C be targets for lipid therapy? A review of current evidence. Journal of Clinical Lipidology 2007;1(1):88–94.

Bruno-Joyce J, Dugas JM, MacCausland OE. Cerivastatin and gemfibrozil-associated rhabdomyolysis [see comment]. Ann Pharmacother 2001;35(9):1016–1019.

Brunzell JD, Davidson M, Furberg CD, et al. Lipoprotein management in patients with cardiometabolic risk: consensus conference report from the American Diabetes Association and the American College of Cardiology Foundation [review] [93 refs]. J Am Coll Cardiol 2008;51(15):1512–1524.

Bulut D, Hanefeld C, Bulut-Streich N, et al. Endothelial function in the forearm circulation of patients with the metabolic syndrome—effect of different lipid-lowering regimens [see comment]. Cardiology 2005;104(4):176–180.

Burnett JR, Moses EA, Croft KD, et al. Clinical and biochemical features, molecular diagnosis and long-term management of a case of cerebrotendinous xanthomatosis. Clin Chim Acta 2001;306(1–2):63–69.

Burnett JR. Torcetrapib + atorvastatin Pfizer. Curr Opin Investig Drugs 2005;6(9):944–950.

Buse JB. Action to Control Cardiovascular Risk in Diabetes (ACCORD) Trial: Design and Methods. Am J Cardiol 2007;(12 SUPPL.):S21–S33.

Bush W. Preventing cardiovascular complications in renal transplant recipients. U 2007;S. Pharmacist. 32(1):HS3–HS17.

Caggiula AW, Watson JE, Kuller LH, et al. Cholesterol-lowering intervention program. Effect of the step I diet in community office practices [see comment]. Arch Intern Med 1996;156(11):1205–1213.

Cahoon Jr. WD, Crouch MA. Preprocedural statin therapy in percutaneous coronary intervention [review] [29 refs]. Ann Pharmacother 2007;41(10):1687–1693.

Campeau L, Knatterud. The effect of aggressive lowering of low-density lipoprotein cholesterol levels and low-dose anticoagulation on obstructive changes in saphenous-vein coronary-artery bypass grafts. N Engl J Med 1997;(3):153–162.

Cannon CP, Braunwald E, McCabe CH, et al. Intensive versus moderate lipid lowering with statins after acute coronary syndromes [see comment]. N Engl J Med 2004;350(15):1495–1504.

Capps N. Case study 1. Familial hyperlipidaemia. British Journal of Diabetes and Vascular Disease 2004;4(Suppl 1):S26–S27.

Capps N. Total and low-density lipoprotein cholesterol responses to ezetimibe in clinical practice. Int J Clin Pract 2006;60(7):867–869.

Capuzzi DM, Morgan JM, Weiss R, et al. Effects of rosuvastatin alone and combined with extended-release niacin on Apo B- and Apo A-containing lipoproteins and triglycerides in atherogenic dyslipidemia. Atheroscler Suppl 2002;3(2):82.

Carmena R, De Oya M, Gomez-Gerique J, et al. Pravastatin, cholestyramine, and bezafibrate in patients with heterozygous familial hypercholesterolemia: The Spanish Multicenter Pravastatin Study. Cardiovascular Risk Factors 1996;6(1):55–61.

Caroli-Bosc FX, Le Gall P, Pugliese P, et al. Role of fibrates and HMG-CoA reductase inhibitors in gallstone formation: epidemiological study in an unselected population. Digestive Diseases & Sciences 2001;46(3):540–544.

Carrero JJ, Lopez-Huertas E, Salmeron LM, et al. Simvastatin and supplementation with omega-3 polyunsaturated fatty acids and vitamins improves claudication distance in a randomized PILOT study in patients with peripheral vascular disease. Nutrition Research 2006; 26(12):637–643.

Carrington M, Stewart S. Is fenofibrate a cost-saving treatment for middle-aged individuals with type II diabetes? An economic analysis of the FIELD Study. Int J Cardiol 2008;127(1):51–56.

Carvalho AA, Lima UW, Valiente RA. Statin and fibrate associated myopathy: study of eight patients. Arq Neuropsiquiatr 2004;62(2A):257–261.

Castro Cabezas M, Erkelens DW, Kock LA, et al. Postprandial apolipoprotein B100 and B48 metabolism in familial combined hyperlipidaemia before and after reduction of fasting plasma triglycerides. Eur J Clin Invest 1994;24(10):669–678.

Chang JT, Staffa JA, Parks M, et al. Rhabdomyolysis with HMG-CoA reductase inhibitors and gemfibrozil combination therapy [see comment]. Pharmacoepidemiol Drug Saf 2004;13(7):417–426.

Chatley P, Badyal DK, Calton R, et al. Combination therapy of low-dose atorvastatin and fenofibrate in mixed hyperlipidemia. Methods Find Exp Clin Pharmacol 2007;29(3):217–221.

Cheng AY, Leiter LA. Implications of recent clinical trials for the National Cholesterol Education Program Adult Treatment Panel III guidelines [review] [15 refs]. Curr Opin Cardiol 2006;21(4):400–404.

Chironi G, Simon A, Gariepy J, et al. Differential associations of statin and fibrate treatment with carotid arterial remodeling. Am J Hypertens 2005;18(11):1476–1481.

Chodorowski Z, Sein Anand J, Madaliski M, et al. Enzymatic examination of potential interaction between statins or fibrates and consumed Tricholoma equestre. Przegl Lek 2005;62(6):468–470.

Cholesterol Treatment Trialists’ (CTT) Collaborators, Kearney PM, Blackwell L, et al. Efficacy of cholesterol-lowering therapy in 18,686 people with diabetes in 14 randomised trials of statins: a meta-analysis [see comment]. Lancet 2008;371(9607):117–125.

Chrysant SG, Ibrahim M. Niacin-ER/statin combination for the treatment of dyslipidemia: focus on low high-density lipoprotein cholesterol [review] [49 refs]. J Clin Hypertens 2006;8(7):493–499.

Chrysanthopoulos C, Kounis N. Rhabdomyolysis due to combined treatment with lovastatin and cholestyramine. BMJ 1992;304(6836):1225.

Chuang P, Langone AJ. Ezetimibe reduces low-density lipoprotein cholesterol (LDL-C) in renal transplant patients resistant to HMG-CoA reductase inhibitors. Am J Ther 2007;14(5):438–441.

Chucrallah A, De Girolami U, Freeman R, et al. Lovastatin/gemfibrozil myopathy: a clinical, histochemical, and ultrastructural study. Eur Neurol 1992;32(5):293–296.

Chuo JY, Wiens M, Etminan M, et al. Use of lipid-lowering agents for the prevention of age-related macular degeneration: a meta-analysis of observational studies [review] [61 refs]. Ophthalmic Epidemiol 2007;14(6):367–374.

Cobb MM, Salen G, Tint GS, et al. Sitosterolemia: opposing effects of cholestyramine and lovastatin on plasma sterol levels in a homozygous girl and her heterozygous father. Metabolism: Clinical & Experimental 1996;45(6):673–679.

Codario RA. Hypertriglyceridemia and cardiovascular disease management. J Am Acad Nurse Pract 2007;19(12 Suppl 2):7–10.

Coleman CI, Reinhart K, Kluger J, et al. The effect of statins on the development of new-onset type 2 diabetes: a meta-analysis of randomized controlled trials [review] [10 refs]. Curr Med Res Opin 2008;24(5):1359–1362.

Conforti A, Leone. Spontaneous reporting of drug-related hepatic reactions from two Italian regions [Lombardy and Veneto]. Dig Liver Dis 2000;(8):716–723.

Conforti A, Magro L, Moretti U, et al. Fluvastatin and hepatic reactions: a signal from spontaneous reporting in Italy. Drug Saf 2006;29(12):1163–1172.

Contacos C, Barter PJ, Sullivan DR. Effect of pravastatin and omega-3 fatty acids on plasma lipids and lipoproteins in patients with combined hyperlipidemia. Arteriosclerosis & Thrombosis 1993;13(12):1755–1762.

Cook JR, Yin D, Alemao E, et al. Development and validation of a model to project the long-term benefit and cost of alternative lipid-lowering strategies in patients with hypercholesterolaemia. Pharmacoeconomics 2004;22(Suppl 3):37–48.

Corbelli JC, Bullano MF, Willey VJ, et al. Effects of gemfibrozil conversion to fenofibrate on lipids in patients on statin therapy. Am J Cardiol 2002;90(12):1388–1391.

Corrao G, Zambon A, Bertu L, et al. Lipid lowering drugs prescription and the risk of peripheral neuropathy: an exploratory case-control study using automated databases. Journal of Epidemiology & Community Health 2004;58(12):1047–1051.

Cramariuc D, Rieck AE, Staal EM, et al. Factors influencing left ventricular structure and stress-corrected systolic function in men and women with asymptomatic aortic valve stenosis (a SEAS Substudy). Am J Cardiol 2008;101(4):510–515.

Crook MA, Lynas J, Wray R. A paradoxical severe decrease in serum HDL-cholesterol after treatment with a fibrate [see comment]. J Clin Pathol 2000;53(10):796–797.

Cross J, Donovan JL, Silva MA, et al. Pharmacologic management of post-acute coronary syndrome. U 2007;S. Pharmacist. 32(2)

Cubeddu LX, Cubeddu RJ, Heimowitz T, et al. Comparative lipid-lowering effects of policosanol and atorvastatin: a randomized, parallel, double-blind, placebo-controlled trial. Am Heart J 2006;152(5):982–985.

Curtin PO, Jones WN. Therapeutic rationale of combining therapy with gemfibrozil and simvastatin. J Am Pharm Assoc (Wash) 2007;47(2):140–146.

Cuthbert JA, East CA, Lipsky PE. Normalization of LDL receptor function by lymphocytes of patients with heterozygous familial hypercholesterolemia after treatment with plasma cholesterol lowering agents. Am J Med Sci 1989;298(3):152–160.

Da Col PG, Fonda M, Fisicaro M, et al. Tolerability and efficacy of combination therapy with simvastatin plus gemfibrozil in type IIb refractory familial combined hyperlipidemia. Curr Ther Res Clin Exp 1993;53(5):473–483.

Danchin N, Cambou JP, Hanania G, et al. Impact of combined secondary prevention therapy after myocardial infarction: data from a nationwide French registry. Am Heart J 2005;150(6):1147–1153.

Darling GM, Johns JA, McCloud PI, et al. Concurrent use of simvastatin and estrogen—progestin therapy compared with each therapy alone for hypercholesterolemia in postmenopausal women. Climacteric 1999;2(3):181–188.

Davidson MH, Ballantyne CM, Kerzner B, et al. Efficacy and safety of ezetimibe coadministered with statins: randomised, placebo-controlled, blinded experience in 2382 patients with primary hypercholesterolemia. Int J Clin Pract 2004;58(8):746–755.

Davidson MH. Combination therapy for dyslipidemia: safety and regulatory considerations. Am J Cardiol 2002;90(10B):50K–60K.

Davidson MH. Efficacy of simvastatin and ezetimibe in treating hypercholesterolemia [comment]. J Am Coll Cardiol 2003;42(2):398–399.

Davignon JX. Lovastatin 5-year safety and efficacy study. Arch Intern Med 1993;(9):1079–1087.

Davignon J, Roederer G, Montigny M, et al. Comparative efficacy and safety of pravastatin, nicotinic acid and the two combined in patients with hypercholesterolemia. Am J Cardiol 1994;73(5):339–345.

Davis M. Case study. A woman with high lipid levels and poor drug tolerance. British Journal of Cardiology 2004;11(Suppl 3):S28–S29.

Davis TM, Yeap BB, Davis WA, et al. Lipid-lowering therapy and peripheral sensory neuropathy in type 2 diabetes: the Fremantle Diabetes Study. Diabetologia 2008;51(4):562–566.

de Alava E, Sola JJ, Lozano MD, et al. Rhabdomyolysis and acute renal failure in a heart transplant recipient treated with hypolipemiants. Nephron 1994;66(2):242–243.

De Buyzere ML, Clement DL. Management of hypertension in peripheral arterial disease [review] [157 refs]. Prog Cardiovasc Dis 2008; 50(4):238–263.

Dedhia V, Munsi SC. Myopathy caused by a combination rosuvastatin and fenofibrate. J Assoc Physicians India 2007;55152–153.

Denke MA, Grundy SM. Efficacy of low-dose cholesterol-lowering drug therapy in men with moderate hypercholesterolemia. Arch Intern Med 1995;155(4):393–399.

Derosa G, Mugellini A, Ciccarelli L, et al. Efficacy of fluvastatin together with fenofibrate in hypercholesterolemic type 2 diabetic subjects compared to monotherapy. Atheroscler Suppl 2002;3(2):100.

Derosa G, Mugellini A, Ciccarelli L, et al. Randomized, double-blind, placebo-controlled comparison of the action of orlistat, fluvastatin, or both an anthropometric measurements, blood pressure, and lipid profile in obese patients with hypercholesterolemia prescribed a standardized diet. Clin Ther 2003;25(4):1107–1122.

Desager JP, Horsmans Y, Harvengt C. Lecithin: cholesterol acyltransferase activity in familial hypercholesterolemia treated with simvastatin and simvastatin plus low-dose colestipol. J Clin Pharmacol 1991;31(6):537–542.

Devroey D, Betz W. An analysis of first authorizations for lipid-lowering drugs in Belgium [comment]. Acta Clin Belg 2003;58(3):152–158.

DeWilde S, Carey IM, Richards N, et al. Trends in secondary prevention of ischaemic heart disease in the UK 1994 2005: use of individual and combination treatment [see comment]. Heart 2008;94(1):83–88.

Diepeveen SH, Verhoeven GW, Van Der, et al. Effects of atorvastatin and vitamin E on lipoproteins and oxidative stress in dialysis patients: a randomised-controlled trial. J Intern Med 2005;257(5):438–445.

Diercks GF, Janssen WM, van Boven AJ, et al. Rationale, design, and baseline characteristics of a trial of prevention of cardiovascular and renal disease with fosinopril and pravastatin in nonhypertensive, nonhypercholesterolemic subjects with microalbuminuria (the Prevention of REnal and Vascular ENdstage Disease Intervention Trial [PREVEND IT]). Am J Cardiol 2000;86(6):635–638.

Dorval JF, Anderson T, Buithieu J, et al. Reaching recommended lipid and blood pressure targets with amlodipine/atorvastatin combination in patients with coronary heart disease. Am J Cardiol 2005;95(2):249–253.

Dotti MT, Lutjohann D, von Bergmann K, et al. Normalisation of serum cholestanol concentration in a patient with cerebrotendinous xanthomatosis by combined treatment with chenodeoxycholic acid, simvastatin and LDL apheresis. Shinkei Kenkyu No Shimpo 2004;25(4):185–191.

Dourakis SP. Statins and hepatotoxicity. Annals of Gastroenterology 2006;19(4):311–312.

Drazen JM, Jarcho JA, Morrissey S et al. Cholesterol lowering and ezetimibe [comment]. N Engl J Med 2008;358(14):1507–1508.

Drugs for lipids [review] [36 refs]. Treat Guidel Med Lett 2008;6(66):9–16.

Duell PB, Connor WE, Illingworth DR. Rhabdomyolysis after taking atorvastatin with gemfibrozil. Am J Cardiol 1998;81(3):368–369.

Dujovne CA. The lovastatin-niacin trial: adverse events [abstract]. Arteriosclerosis and thrombosis: a journal of vascular biology. American Heart Association 1991;11(5):1458A.

Durham HL, Mushatt DM, Kemmerly SA, et al. Cellulitis in a fisherman. Infect Med 2003;20(12):578–581.

Duvall WL, Blazing MA, Saxena S, et al. Targeting cardiovascular risk associated with both low density and high density lipoproteins using statin-niacin combination therapy. J Cardiovasc Risk 2002;9(6):339–347.

East C, Bilheimer DW, Grundy SM. Combination drug therapy for familial combined hyperlipidemia. Ann Intern Med 1988;109(1):25–32.

Efrati S, Averbukh M, Dishy V, et al. The effect of simvastatin, ezetimibe and their combination on the lipid profile, arterial stiffness and inflammatory markers. Eur J Clin Pharmacol 2007;63(2):113–121.

Egan DA, Garg R, Wilt TJ, et al. Rationale and design of the Arterial Disease Multiple Intervention Trial (ADMIT) pilot study. Am J Cardiol 1999;83(4):569–575.

Eliav O, Schurr D, Pfister P, et al. High-dose fluvastatin and bezafibrate combination treatment for heterozygous familial hypercholesterolemia. Am J Cardiol 1995;76(2):76A–79A.

Ellen RL, McPherson R. Long-term efficacy and safety of fenofibrate and a statin in the treatment of combined hyperlipidemia [review] [26 refs]. Am J Cardiol 1998;81(4A):60B–65B.

Elmberger PG, Kalen A, Lund E, et al. Effects of pravastatin and cholestyramine on products of the mevalonate pathway in familial hypercholesterolemia. J Lipid Res 1991;32(6):935–940.

Emmerich J, Aubert I, Bauduceau B, et al. Efficacy and safety of simvastatin (alone or in association with cholestyramine). A 1-year study in 66 patients with type II hyperlipoproteinaemia. Eur Heart J 1990;11(2):149–155.

Erkelens DW, Baggen MG, Van Doormaal JJ, et al. Clinical experience with simvastatin compared with cholestyramine. Drugs 1988;36(Suppl 3):87–92.

Evaluation of Choline Fenofibrate (ABT-335) on Carotid Intima Media Thickness (cIMT) in Subjects with Type IIa and IIb Dyslipidemia with Residual Risk in Addition to Atorvastatin Therapy (FIRST) trial. 2008.

Fagerberg B, Wikstrand J, Berglund G, et al. Mortality rates in treated hypertensive men with additional risk factors are high but can be reduced: a randomized intervention study. Am J Hypertens 1998;11(1 Pt 1):14–22.

Falagas ME, Makris GC, Matthaiou DK, et al. Statins for infection and sepsis: a systematic review of the clinical evidence [review] [36 refs]. J Antimicrob Chemother 2008;61(4):774–785.

Faludi AA, Aldrighi JM, Bertolami MC, et al. Progesterone abolishes estrogen and/or atorvastatin endothelium dependent vasodilatory effects [see comment]. Atherosclerosis 2004;177(1):89–96.

Farlow MR, Miller ML, Pejovic V. Treatment options in Alzheimer’s disease: maximizing benefit, managing expectations [review] [183 refs]. Dement Geriatr Cogn Disord 2008;25(5):408–422.

Farnier M, Bortolini M, Salko T, et al. Frequency of creatine kinase elevation during treatment with fluvastatin in combination with fibrates (bezafibrate, fenofibrate, or gemfibrozil). Am J Cardiol 2003;91(2):238–240.

Farnier M, Dejager S. Effect of combined fluvastatin-fenofibrate therapy compared with fenofibrate monotherapy in severe primary hypercholesterolemia. Am J Cardiol 2000;85(1):53–57.

Farnier M, Dejager S. Effect of combined fluvastatin-fenofibrate therapy compared with fenofibrate monotherapy in severe primary hypercholesterolemia. French Fluvastatin Study Group. Am J Cardiol 2000;85(1):53–57.

Farnier M, Salko T, Isaacsohn JL, et al. Effects of baseline level of triglycerides on changes in lipid levels from combined fluvastatin + fibrate (bezafibrate, fenofibrate, or gemfibrozil). Am J Cardiol 2003;92(7):794–797.

Fauchier L, Pierre B, de LA, et al. Antiarrhythmic effect of statin therapy and atrial fibrillation a meta-analysis of randomized controlled trials. J Am Coll Cardiol 2008;51(8):828–835.

Fauler G, Abletshauser C, Erwa W, et al. Time-of-intake (morning versus evening) of extended-release fluvastatin in hyperlipemic patients is without influence on the pharmacodynamics (mevalonic acid excretion) and pharmacokinetics. International Journal of Clinical Pharmacology & Therapeutics 2007;45(6):328–334.

Federman DG, Hussain F, Walters AB. Fatal rhabdomyolysis caused by lipid-lowering therapy. South Med J 2001;94(10):1023–1026.

Feeman Jr WE. Statin-fibrate combination therapy [comment]. Am J Cardiol 2008;101(10):1521.

Fegan PG, Shore AC, Mawson D, et al. Microvascular endothelial function in subjects with Type 2 diabetes and the effect of lipid-lowering therapy. Diabet Med 2005;22(12):1670–1676.

Feher MD, Foxton J, Banks D, et al. Long-term safety of statin-fibrate combination treatment in the management of hypercholesterolaemia in patients with coronary artery disease [see comment]. Br Heart J 1995;74(1):14–17.

Feher MD, Webb JC, Patel DD, et al. Cholesterol-lowering drug therapy in a patient with receptor-negative homozygous familial hypercholesterolaemia. Atherosclerosis 1993;103(2):171–180.

Feldman T, Davidson M, Shah A, et al. Comparison of the lipid-modifying efficacy and safety profiles of ezetimibe coadministered with simvastatin in older versus younger patients with primary hypercholesterolemia: A post Hoc analysis of subpopulations from three pooled clinical trials. Clin Ther 2006;28(6):849–859.

Feussner G, Eichinger M, Ziegler R. The influence of simvastatin alone or in combination with gemfibrozil on plasma lipids and lipoproteins in patients with type III hyperlipoproteinemia. Clin Investig 1992;70(11):1027–1035.

Fichtlscherer S, Schmidt-Lucke C, Bojunga S, et al. Differential effects of short-term lipid lowering with ezetimibe and statins on endothelial function in patients with CAD: clinical evidence for ‘pleiotropic’ functions of statin therapy. Eur Heart J 2006;27(10):1182–1190.

Firdaus M, Sivaram CA, Reynolds DW. Prevention of cardiovascular events by treating hypertension in older adults: an evidence-based approach [review] [51 refs]. J Clin Hypertens (Greenwich ) 2008;10(3):219–225.

Fish oil supplements. Medical Letter on Drugs and Therapeutics 2006;48(1239):59–60.

Fish, seal, and flaxseed oils lessened joint pain. J Fam Pract 2007;56(8):615.

Florentin M, Liberopoulos EN, Elisaf MS. Ezetimibe-associated adverse effects: what the clinician needs to know [review] [91 refs]. Int J Clin Pract 2008; 62(1):88–96.

Florentin M, Liberopoulos EN, Mikhailidis DP, et al. Colesevelam hydrochloride in clinical practice: a new approach in the treatment of hypercholesterolaemia [review] [97 refs]. Curr Med Res Opin 2008;24(4):995–1009.

Flores J. Ezetimiba. Nutr Metab Disord HIV Infect 2005;4(2):730–732.

Fonseca FAH. A new vision of coronary atherosclerosis. International Journal of Atherosclerosis 2007;2(3):207–208.

Fortuny J, de Sanjose S, Becker N, et al. Statin use and risk of lymphoid neoplasms: results from the European Case-Control Study EPILYMPH. Cancer Epidemiol Biomarkers Prev 2006;15(5):921–925.

Fox KM, Gandhi SK, Ohsfeldt RL, et al. Effectiveness of rosuvastatin in low-density lipoprotein cholesterol lowering and National Cholesterol Education Program Adult Treatment Panel guideline III LDL-C goal attainment compared to other statins among diabetes mellitus patients: a retrospective study using an electronic medical records dataset in the United States. Curr Med Res Opin 2007;23(9):2125–2133.

Friedman M. Are all fish equally close to the heart? [comment]. Mayo Clin Proc 2008;83(6):724–725.

Fux R, Morike K, Gundel UF, et al. Ezetimibe and statin-associated myopathy [see comment]. Ann Intern Med 2004;140(8):671–672.

Gadarla M, Kearns AK, Thompson PD. Efficacy of rosuvastatin (5 mg and 10 mg) twice a week in patients intolerant to daily statins. Am J Cardiol 2008;101(12):1747–1748.

Ganotakis ES, Jagroop IA, Hamilton G, et al. Preliminary report: ciprofibrate-fluvastatin combination therapy for dyslipidaemia. J Drug Dev 1996;8(3):171–175.

Gao F, Hu XF. Effect of Taizhi’an capsule combined with Simvastatin on hyperlipidemia in diabetic patients. Chinese Journal of Integrative Medicine 2006;12(1):24–28.

Gardner SF, Marx MA, White LM, et al. Combination of low-dose niacin and pravastatin improves the lipid profile in diabetic patients without compromising glycemic control. Ann Pharmacother 1997;31(6):677–682.

Garg A, Grundy SM. Gemfibrozil alone and in combination with lovastatin for treatment of hypertriglyceridemia in NIDDM [erratum appears in Diabetes 1990 Oct;39(10):1313]. Diabetes 1989;38(3):364–372.

Garg A, Grundy SM. Gemfibrozil alone and in combination with lovastatin for treatment of hypertriglyceridemia in NIDDM. Diabetes 1989;38(3):364–372.

Gavish D, Leibovitz E, Shapira I, et al. Bezafibrate and simvastatin combination therapy for diabetic dyslipidaemia: efficacy and safety. J Intern Med 2000;247(5):563–569.

Gaw A, Packard CJ, Lindsay GM, et al. Effects of colestipol alone and in combination with simvastatin on apolipoprotein B metabolism. Arteriosclerosis, Thrombosis & Vascular Biology 1996;16(2):236–249.

Gazi IF, Daskalopoulou SS, Nair DR, et al. Effect of ezetimibe in patients who cannot tolerate statins or cannot get to the low density lipoprotein cholesterol target despite taking a statin. Curr Med Res Opin 2007;23(9):2183–2192.

Gerich JE. Type 2 diabetes mellitus is associated with multiple cardiometabolic risk factors [review] [95 refs]. Clin Cornerstone 2007;8(3):53–68.

Gil-Extremera B, Mendez G, Zakson M, et al. Efficacy and safety of ezetimibe/simvastatin co-administered with fenofibrate in mixed hyperlipidemic patients with metabolic syndrome. Metabolic Syndrome and Related Disorders 2007;5(4):305–314.

Ginsberg HN, Bonds DE, Lovato LC, et al. Evolution of the lipid trial protocol of the Action to Control Cardiovascular Risk in Diabetes (ACCORD) trial. Am J Cardiol 2007;99(12A):56i–67i.

Gislason GH, Rasmussen JN, Abildstrom SZ, et al. Persistent use of evidence-based pharmacotherapy in heart failure is associated with improved outcomes [see comment]. Circulation 2007;116(7):737–744.

Glueck CJ, Oakes N, Speirs J, et al. Gemfibrozil-lovastatin therapy for primary hyperlipoproteinemias [see comment]. Am J Cardiol 1992;70(1):1–9.

Glueck CJ, Speirs J, Tracy T. Safety and efficacy of combined gemfibrozil-lovastatin therapy for primary dyslipoproteinemias. Journal of Laboratory & Clinical Medicine 1990;115(5):603–609.

Goldberg RB, Jacobson TA. Effects of niacin on glucose control in patients with dyslipidemia [review] [49 refs]. Mayo Clin Proc 2008;83(4):470–478.

Goldkind L, Laine L. A systematic review of NSAIDs withdrawn from the market due to hepatotoxicity: lessons learned from the bromfenac experience [see comment]. Pharmacoepidemiology & Drug Safety 2006;15(4):213–220.

Goldman JA, Fishman AB, Lee JE, et al. The role of cholesterol-lowering agents in drug-induced rhabdomyolysis and polymyositis. Arthritis & Rheumatism 1989;32(3):358–359.

Gonzalez CA, Rubio-Guerra AF, Pavia A, et al. Effectiveness and safety of ezetimibe added to statin therapy in patients with primary dyslipidaemia not achieving the LDL-C treatment goal on statin monotherapy. Clin Drug Investig 2007;27(5):333–337.

Goosen TC, Bauman JN, Davis JA, et al. Atorvastatin glucuronidation is minimally and nonselectively inhibited by the fibrates gemfibrozil, fenofibrate, and fenofibric acid. Drug Metab Dispos 2007;35(8):1315–1324.

Greenland P, Lloyd-Jones D. Critical lessons from the ENHANCE trial. JAMA 2008; 299(8):953–955.

Grundy SM, Vega GL, Bilheimer DW. Influence of combined therapy with mevinolin and interruption of bile-acid reabsorption on low density lipoproteins in heterozygous familial hypercholesterolemia. Ann Intern Med 1985;103(3):339–343.

Guha S, Pal SK, Chatterjee N, et al. Effect of chitosan on lipid levels when administered concurrently with atorvastatin—a placebo controlled study. J Indian Med Assoc 2005;103(8):418.

Gustavson LE, Schweitzer SM, Koehne-Voss S, et al. The effects of multiple doses of fenofibrate on the pharmacokinetics of pravastatin and its 3alpha-hydroxy isomeric metabolite. J Clin Pharmacol 2005;45(8):947–953.

Guyton JR, Goldberg AC, Kreisberg RA, et al. Effectiveness of once-nightly dosing of extended-release niacin alone and in combination for hypercholesterolemia. Am J Cardiol 1998;82(6):737–743.

Guyton JR, Brown BG, Fazio S, et al. Lipid-altering efficacy and safety of ezetimibe/simvastatin coadministered with extended-release niacin in patients with type IIa or type IIb hyperlipidemia. J Am Coll Cardiol 2008;51(16):1564–1572.

Guyton JR. Niacin in cardiovascular prevention: mechanisms, efficacy, and safety [review] [70 refs]. Curr Opin Lipidol 2007;18(4):415–420.

Gylling H, Miettinen TA. LDL cholesterol lowering by bile acid malabsorption during inhibited synthesis and absorption of cholesterol in hypercholesterolemic coronary subjects. Nutrition Metabolism & Cardiovascular Diseases 2002;12(1):19–23.

Habib G, Paillard F, Charpentier G, et al. A multicenter, open-label, randomized study comparing the efficacy of atorvastatin versus usual care in reducing refractory hypercholesterolemia in high-risk patients to target levels. Current Therapeutic Research, Clinical & Experimental 2000;61(4):175–190.

Hackman A, Abe Y, Insull W, et al. Levels of soluble cell adhesion molecules in patients with dyslipidemia. Circulation 1996;93(7):1334–1338.

Hagen E, Istad H, Ose L, et al. Fluvastatin efficacy and tolerability in comparison and in combination with cholestyramine. Eur J Clin Pharmacol 1994;46(5):445–449.

Hamilton-Craig I. Medicinal mishap: Statin-fibrate combination therapy. Australian Prescriber 2001;24(5):109.

Hansen KE, Hildebrand JP, Ferguson EE, et al. Outcomes in 45 patients with statin-associated myopathy. Arch Intern Med 2005;165(22):2671–2676.

Harley CR, Gandhi SK, Anoka N, et al. Understanding practice patterns and low-density lipoprotein cholesterol goal attainment implications of switching patients from simvastatin in a health plan setting [review] [17 refs]. Am J Manag Care 2007;13 Suppl 10:S276–S281.

Harris WS. Does treatment with eicosapentaenoic acid prevent major coronary events in patients with hypercholesterolemia?: Commentary. Nat Clin Pract Cardiovasc Med 2007;4(10):532–533.

Harrow C, Fisher M. Is there a role for omega 3 supplementation in diabetes? Practical Diabetes International 2007;24(9):443–444.

Harry Mandeville W, Arbeeny C. Bile acid sequestrants: their use in combination with other lipid-lowering agents. IDrugs 1999;2(3):237–242.

Hartweg J, Farmer AJ, Perera R, et al. Meta-analysis of the effects of n-3 polyunsaturated fatty acids on lipoproteins and other emerging lipid cardiovascular risk markers in patients with type 2 diabetes [review] [73 refs]. Diabetologia 2007;50(8):1593–1602.

Haskell WL, Alderman EL, Fair JM, et al. Effects of intensive multiple risk factor reduction on coronary atherosclerosis and clinical cardiac events in men and women with coronary artery disease. The Stanford Coronary Risk Intervention Project (SCRIP). Circulation 1994;89(3):975–990.

Hausenloy DJ, Yellon DM. Targeting residual cardiovascular risk: raising high-density lipoprotein cholesterol levels [see comment] [review] [122 refs]. Heart 2008;94(6):706–714.

Hecht HS, Harman SM. Comparison of effectiveness of statin monotherapy versus statin and niacin combination therapy in primary prevention and effects on calcified plaque burden. Am J Cardiol 2003;91(3):348–351.

Hecht HS, Harman SM. Comparison of the effects of atorvastatin versus simvastatin on subclinical atherosclerosis in primary preventionas determined by electronbeam tomography. Am J Cardiol 2003;91(1):42–45.

Hecht HS, Harman SM. Relation of aggressiveness of lipid-lowering treatment to changes in calcified plaque burden by electron beam tomography. Am J Cardiol 2003;92(3):334–336.

Heerey A, Barry. The potential for drug interactions with statin therapy in Ireland. Ir J Med Sci 2000;(3):176–179.

Help for your cholesterol when statins won’t do. If you are one of the many, but also one of the few. Harv Mens Health Watch 2005;9(8):1–4.

Hendriks F, Kooman JP, van der, et al. Massive rhabdomyolysis and life threatening hyperkalaemia in a patient with the combination of cerivastatin and gemfibrozil. Nephrology Dialysis Transplantation 2001;16(12):2418–2419.

Hendriksz CJ, Norbury G, Tabrah S, et al. Homozygous hypercholesterolaemia and ezetimibe: a case report. Acta Paediatr 2004;93(2):280–282.

Henkin Y, Oberman A, Hurst DC, et al. Niacin revisited: clinical observations on an important but underutilized drug. Am J Med 1991;91(3):239–246.

Henyan NN, Riche DM, East HE, et al. Impact of statins on risk of stroke: a meta-analysis [see comment]. Ann Pharmacother 2007;41(12):1937–1945.

Heudebert GR, Van Ruiswyk J, Hiatt J, et al. Combination drug therapy for hypercholesterolemia. The trade-off between cost and simplicity. Arch Intern Med 1993;153(15):1828–1837.

Hey-Hadavi JH, Kuntze E, Luo D, et al. Tolerability of atorvastatin in a population aged > or =65 years: a retrospective pooled analysis of results from fifty randomized clinical trials. American Journal Geriatric Pharmacotherapy 2006;4(2):112–122.

Hiatt JG, Shamsie SG, Schectman G. Discontinuation rates of cholesterol-lowering medications: implications for primary care. Am J Manag Care 1999;5(4):437–444.

Hildemann SK, Barho C, Karmann B, et al. Dual cholesterol inhibition with ezetimibe/simvastatin in pretreated hypercholesterolaemic patients with coronary heart disease or diabetes mellitus: Prospective observational cohort studies in clinical practice. Curr Med Res Opin 2007;23(4):713–719.

Hill MD, Bilbao JM. Case of the month: February 1999—54 year old man with severe muscle weakness. Brain Pathol 1999;9(3):607–608.

Hippisley-Cox J, Coupland C. Effect of combinations of drugs on all cause mortality in patients with ischaemic heart disease: nested case-control analysis [see comment]. BMJ 2005;330(7499):1059–1063.

Hirschfield G. Effects of fluvastatin and bezafibrate combination on plasma fibrinogen, t-plasminogen activator inhibitor and C reactive protein levels in coronary artery disease patients with mixed hyperlipidaemia (FACT Study)—a rebuttal [comment]. Thrombosis & Haemostasis 2001;85(1):189–190.

Hoeg JM, Maher MB, Bailey KR, et al. Comparison of six pharmacologic regimens for hypercholesterolemia. Am J Cardiol 1987;59(8):812–815.

Hollenberg NK. Simvastatin and niacin, antioxidant vitamins, or the combination for the prevention of coronary disease. Curr Hypertens Rep 2002;4(4):270–271.

Hoogerbrugge N, Jansen H, De Heide L, et al. The additional effects of acipimox to simvastatin in the treatment of combined hyperlipidaemia [republished from J Intern Med. 1997 Feb;241(2):151–5; PMID: 9077372]. J Intern Med 1998;243(5):151–156.

Hoogerbrugge N, Mol MJ, Van Dormaal JJ, et al. The efficacy and safety of pravastatin, compared to and in combination with bile acid binding resins, in familial hypercholesterolaemia [see comment]. J Intern Med 1990;228(3):261–266.

Hoogerbrugge N. Effects of atorvastatin on serum lipids of patients with familial hypercholesterolaemia. J Intern Med 1998;244(2):143–147.

Horsmans Y, Desager JP, Harvengt C. Effects of combined bezafibrate-simvastatin appraised in healthy subjects. J Clin Pharmacol 1992;32(5):422–426.

Horvath A, Koletzko B, Szajewska H. Effect of supplementation of women in high-risk pregnancies with long-chain polyunsaturated fatty acids on pregnancy outcomes and growth measures at birth: A meta-analysis of randomized controlled trials. Br J Nutr 2007;98(2):253–259.

Howard PA, Barnes BJ. Potential use of statins to prevent atrial fibrillation after coronary artery bypass surgery [review] [26 refs]. Ann Pharmacother 2008;42(2):253–258.

Hudson M, Richard H, Pilote L. Parabolas of medication use and discontinuation after myocardial infarction—are we closing the treatment gap? Pharmacoepidemiology & Drug Safety 2007;16(7):773–785.

Hung YJ, Pei D, Wu DA, et al. Effects of lovastatin and gemfibrozil in subjects with high ratios of total cholesterol to high-density lipoprotein cholesterol. J Formos Med Assoc 1999;98(2):104–110.

Hunninghake D, Bakker-Arkema RG, Wigand JP, et al. Treating to meet NCEP-recommended LDL cholesterol concentrations with atorvastatin, fluvastatin, lovastatin, or simvastatin in patients with risk factors for coronary heart disease. J Fam Pract 1998;47(5):349–356.

Husereau DR. Ezetimibe for lowering blood cholesterol. Issues Emerg Health Technol 2003;(49):1–4.

Hussein O, Minasian L, Itzkovich Y, et al. Ezetimibe’s effect on platelet aggregation and LDL tendency to peroxidation in hypercholesterolaemia as monotherapy or in addition to simvastatin. Br J Clin Pharmacol 2008;65(5):637–645.

Hutchesson AC, Moran A, Jones AF. Dual bezafibrate-simvastatin therapy for combined hyperlipidaemia. Journal of Clinical Pharmacy & Therapeutics 1994;19(6):387–389.

Huynh T, Cordato D, Yang F, et al. HMG CoA reductase-inhibitor-related myopathy and the influence of drug interactions. Intern Med J 2002;32(9–10):486–490.

Illingworth DR, Bacon S. Influence of lovastatin plus gemfibrozil on plasma lipids and lipoproteins in patients with heterozygous familial hypercholesterolemia. Circulation 1989;79(3):590–596.

Illingworth DR, Cope R, Bacon SP. Regression of tendon xanthomas in patients with familial hypercholesterolemia treated with lovastatin. South Med J 1990;83(9):1053–1057.

Illingworth DR, O’Malley JP. The hypolipidemic effects of lovastatin and clofibrate alone and in combination in patients with type III hyperlipoproteinemia. Metabolism: Clinical & Experimental 1990;39(4):403–409.

In brief: Zetia and Vytorin: the ENHANCE study. Med Lett Drugs Ther 2008;50(1278):5.

Issa AM, Phillips KA, Van BS, et al. Drug withdrawals in the United States: A systematic review of the evidence and analysis of trends. Current Drug Safety 2007;2(3):177–185.

Jacob BG, Mohrle W, Richter WO, et al. Short- and long-term effects of lovastatin and pravastatin alone and in combination with cholestyramine on serum lipids, lipoproteins and apolipoproteins in primary hypercholesterolaemia. Eur J Clin Pharmacol 1992;42(4):353–358.

Jacob BG, Richter WO, Schwandt P. Long-term treatment (2 years) with the HMG CoA reductase inhibitors lovastatin or pravastatin in combination with cholestyramine in patients with severe primary hypercholesterolemia. J Cardiovasc Pharmacol 1993;22(3):396–400.

Jacob SS, Jacob S, Williams C, et al. Simvastatin, fenofibrate, and rhabdomyolysis. Diabetes Care 2005;28(5):1258.

Jacobson TA, Amorosa LF. Combination therapy with fluvastatin and niacin in hypercholesterolemia: a preliminary report on safety. Am J Cardiol 1994;73(14):25D–29D.

Jacobson TA, Chin MM, Fromell GJ, et al. Fluvastatin with and without niacin for hypercholesterolemia. Am J Cardiol 1994;74(2):149–154.

Jacobson TA, Jokubaitis LA, Amorosa LF. Fluvastatin and niacin in hypercholesterolemia: a preliminary report on gender differences in efficacy. Am J Med 1994;96(6A):64S–68S.

Jacobson TA. Comparative pharmacokinetic interaction profiles of pravastatin, simvastatin, and atorvastatin when coadministered with cytochrome P450 inhibitors. Am J Cardiol 2004;94(9):1140–1146.

Jacobson TA. Beyond lipids: The role of omega-3 fatty acids from fish oil in the prevention of coronary heart disease. Curr Atheroscler Rep 2007;9(2):145–153.

Jacobson TA. Toward “pain-free” statin prescribing: clinical algorithm for diagnosis and management of myalgia [review] [79 refs]. Mayo Clin Proc 2008;83(6):687–700.

Jenkins DJ, Josse AR, Beyene J, et al. Fish-oil supplementation in patients with implantable cardioverter defibrillators: a meta-analysis [see comment] [review] [46 refs]. CMAJ 2008;178(2):157–164.

Johns KW, Bennett MT, Bondy GP. Are HIV positive patients resistant to statin therapy? Lipids Health Dis 2007;6:27.

Johnson A. Red yeast rice and omega-3 fatty acids for cholesterol management. S D Med 2008;61(2):58–59.

Jones PH, Davidson MH. Reporting rate of rhabdomyolysis with fenofibrate + statin versus gemfibrozil + any statin. Am J Cardiol 2005;95(1):120–122.

Jurado J, Seip R, Thompson PD. Effectiveness of ezetimibe in clinical practice. Am J Cardiol 2004;93(5):641–643.

Kaisar MO, Isbel NM, Johnson DW. Recent clinical trials of pharmacologic cardiovascular interventions in patients with chronic kidney disease [review] [69 refs]. Rev Recent Clin Trials 2008;3(2):79–88.

Kajinami K, Kasashima S, Oda Y, et al. Coronary ectasia in familial hypercholesterolemia: histopathologic study regarding matrix metalloproteinases. Mod Pathol 1999;12(12):1174–1180.

Kajinami K, Yagi K, Higashikata T, et al. Low-density lipoprotein receptor genotype-dependent response to cholesterol lowering by combined pravastatin and cholestyramine in familial hypercholesterolemia. Am J Cardiol 1998;82(1):113–117.

Kalofoutis C, Piperi C, Kalofoutis A, et al. Type II diabetes mellitus and cardiovascular risk factors: Current therapeutic approaches. Experimental & Clinical Cardiology 2007;12(1):17–28.

Kane JP, Malloy MJ, Ports TA, et al. Regression of coronary atherosclerosis during treatment of familial hypercholesterolemia with combined drug regimens [see comment]. JAMA 1990;264(23):3007–3012.

Kanters SD, Algra A, de Bruint TW, et al. Intensive lipid-lowering strategy in patients with diabetes mellitus. Diabet Med 1999;16(6):500–508.

Karas RH, Kashyap ML, Knopp RH, et al. Long-term safety and efficacy of a combination of niacin extended release and simvastatin in patients with dyslipidemia: the OCEANS study. Am J Cardiovasc Drugs 2008;8(2):69–81.

Karpa KD. New statin said to be more powerful than others. Drug Topics 2003;147(3):27.

Kashyap ML, McGovern ME, Berra K, et al. Long-term safety and efficacy of a once-daily niacin/lovastatin formulation for patients with dyslipidemia. Am J Cardiol 2002;89(6):672–678.

Kashyap ML, Tavintharan S, Kamanna VS. Optimal therapy of low levels of high density lipoprotein-cholesterol [review] [97 refs]. American Journal of Cardiovascular Drugs 2003;3(1):53–65.

Kasiske BL, Heim-Duthoy KL, Singer GG, et al. The effects of lipid-lowering agents on acute renal allograft rejection. Transplantation 2001;72(2):223–227.

Kastelein JJP, Sankatsing RR. Ezetimibe/simvastatin (INEGY?) in the treatment of hyperlipidaemia. Int J Clin Pract 2005;59(12):1464–1471.

Kastelein JJP. Modifying plasma low-density lipoprotein and high-density lipoprotein cholesterol: What combinations are available in the future? Am J Cardiol 2005;96(9 SUPPL. 1):20K–27K.

Kastelein JJP. The realities of dyslipidaemia: What do the studies tell us? Eur Heart J Suppl 2005;7(F):F27–F33.

Kastelein JJ, Sager PT, de Groot E, et al. Comparison of ezetimibe plus simvastatin versus simvastatin monotherapy on atherosclerosis progression in familial hypercholesterolemia. Design and rationale of the Ezetimibe and Simvastatin in Hypercholesterolemia Enhances Atherosclerosis Regression (ENHANCE) trial. Am Heart J 2005;149(2):234–239.

Kaur K, Rai J, Sharma G, et al. An open-label comparison of the effects of simvastatin and niacin alone and combined on the lipid profile and lipoprotein (a) level in an Indian population with dyslipidemia. Curr Ther Res Clin Exp 2004;65(6):455–469.

Kawashiri MA, Higashikata T, Nohara A, et al. Efficacy of colestimide coadministered with atorvastatin in japanese patients with heterozygous familial hypercholesterolemia (FH). Circ J 2005;69(5):515–520.

Kay J, Finn DS, Stone JR. Case 4-2006: A 79-year-old woman with myalgias, fatigue, and shortness of breath. N Engl J Med 2006;354(6):623–630.

Kazama H, Usui S, Okazaki M, et al. Effects of bezafibrate and pravastatin on remnant-like lipoprotein particles and lipoprotein subclasses in type 2 diabetes. Diabetes Research & Clinical Practice 2003;59(3):181–189.

Kehely A, MacMahon M, Barbir M, et al. Combined bezafibrate and simvastatin treatment for mixed hyperlipidaemia [erratum appears in QJM 1995 Oct;88(10):749]. QJM 1995;88(6):421–427.

Kehely A, MacMahon M. Bezafibrate and simvastatin: an effective and safe combination to treat mixed hyperlipidaemia [abstract]. Clin Sci 1993;85(Suppl 29):20.

Kelly AM, Dwamena B, Cronin P, et al. Meta-analysis: effectiveness of drugs for preventing contrast-induced nephropathy. Ann Intern Med 2008;148(4):284–294.

Khandwala HM. Lipid lowering inefficacy of high-dose statin therapy due to concurrent use of phenytoin. South Med J 2006;99(12):1385–1387.

Kind AH, Zakowski LJ, McBride PE. Rhabdomyolysis from the combination of a statin and gemfibrozil: an uncommon but serious adverse reaction. WMJ 2002;101(7):53–56.

Kitano Y, Thompson GR. The familial hypercholesterolemia regression study: a randomized comparison of therapeutic reduction of both low-density lipoprotein and lipoprotein(a) versus low-density lipoprotein alone. Ther Apher 1997;1(2):187–190.

Klein WW, Jackson G, Tavazzi L. Efficacy of monotherapy compared with combined antianginal drugs in the treatment of chronic stable angina pectoris: a meta-analysis [review] [46 refs]. Coron Artery Dis 2002;13(8):427–436.

Klibanov OM, van den, Berg-Wolf M, et al. Elevations in creatine kinase and hepatic transaminases in an HIV-positive patient. Infect Dis Clin Pract 2006;14(3):181–184.

Klinke JA, Malek F, Gao M, et al. Reaching target lipid levels in patients at high risk of cardiovascular event: the experience of a Canadian tertiary care lipid clinic. Cent Eur J Public Health 2007;15(3):106–109.

Klosiewicz-Latoszek L, Szostak WB, Grzybowska B, et al. Comparison of combined statin-fibrate treatment to monotherapy in patients with mixed hyperlipidemia. Kardiol Pol 2004;60(6):567–577.

Knoll R W, Ciafone R, Galen M. Rhabdomyolysis and renal failure secondary to combination therapy of hyperlipidemia with lovastatin and gemfibozil. Conn Med 1993;57(9):593–594.

Knopp RH, Retzlaff B, Aikawa K, et al. Management of patients with diabetic hyperlipidemia. Am J Cardiol 2003;9(7 Suppl 1):24E–28E.

Knopp RH, Paramsothy P, Atkinson B, et al. Comprehensive lipid management versus aggressive low-density lipoprotein lowering to reduce cardiovascular risk [review] [31 refs]. Am J Cardiol 2008;101(8A):48B–57B.

Knops RE, Kroon AA, Mol MJ, et al. Long-term experience (6 years) with simvastatin in patients with heterozygous familial hypercholesterolaemia. Neth J Med 1995;46(4):171–178.

Ko GT, Mak TW, Yeung VT, et al. Short-term efficacy and tolerability of combination therapy with lovastatin and acipimox in Chinese patients with type 2 diabetes mellitus and mixed dyslipidemia. J Clin Pharmacol 1998;38(10):912–917.

Kobayashi J, Murano S, Yokote K, et al. Marked decrease in plasma apolipoprotein A-I and high density lipoprotein-cholesterol in a case with Werner syndrome. Clin Chim Acta 2000;293(1–2):63–73.

Koh KK, Cardillo C, Bui MN, et al. Vascular effects of estrogen and cholesterol-lowering therapies in hypercholesterolemic postmenopausal women. Circulation 1999;99(3):354–360.

Koh KK, Son JW, Ahn JY, et al. Simvastatin combined with ramipril treatment in hypercholesterolemic patients. Hypertension 2004;44(2):180–185.

Kohnle M, Pietruck F, Kribben A, et al. Ezetimibe for the treatment of uncontrolled hypercholesterolemia in patients with high-dose statin therapy after renal transplantation. Am J Transplant 2006;6(1):205–208.

Kolovou GD, Dedoussis GV, Anagnostopoulou KK, et al. Management of a patient with a null low-density lipoprotein receptor mutation: a case report. Angiology 2006;57(6):729–732.

Kostis JB, Wilson AC, Pan HY, et al. The use of pravastatin alone and in combination with colestipol or probucol in the treatment of primary hypercholesterolemia. Curr Ther Res Clin Exp 1992;51(3):487–494.

Kourimate S, Le MC, Langhi C, et al. Dual mechanisms for the fibrate-mediated repression of proprotein convertase subtilisin/kexin type 9. J Biol Chem 2008;283(15):9666–9673.

Krai BG, Blumenthal RS. Never too old for statins. Cardiology Review 2007;24(9):32–33.

Krappweis J, Aumann. The prescribing of lipid lowering drugs during a 1-year period: analysis of 7490 health insurance files. Pharmacoepidemiol Drug Saf 2000;(2):119–125.

Kreitzer T, Wright A, Shubrook J. A 47-year-old man with eruptions on his trunk. J Fam Pract 2006;55(7):597–599.

Kroon AA, Aengevaeren WR, van der, et al. LDL-Apheresis Atherosclerosis Regression Study (LAARS). Effect of aggressive versus conventional lipid lowering treatment on coronary atherosclerosis. Circulation 1996;93(10):1826–1835.

Kuettner A, Pieper A, Koch J, et al. Influence of coenzyme Q(10) and cerivastatin on the flow-mediated vasodilation of the brachial artery: results of the ENDOTACT study. Int J Cardiol 2005;98(3):413–419.

Kuriyama M, Tokimura Y, Fujiyama J, et al. Treatment of cerebrotendinous xanthomatosis: effects of chenodeoxycholic acid, pravastatin, and combined use. J Neurol Sci 1994;125(1):22–28.

Kursat S, Alici T, Colak HB. A case of rhabdomyolysis induced acute renal failure secondary to statin-fibrate-derivative combination and occult hypothyroidism. Clin Nephrol 2005;64(5):391–393.

Kyrklund C, Backman JT, Neuvonen M, et al. Gemfibrozil increases plasma pravastatin concentrations and reduces pravastatin renal clearance. Clinical Pharmacology & Therapeutics 2003;73(6):538–544.

Lal SM, Habib S. Lipid lowering effects of niacin and lovastatin given alone or with cholestyramine in renal transplant patients [abstract]. Journal of the American Society of Nephrology: JASN 1998;9(Program and Abstracts):683A.

Lal SM, Katyal A. Effects of nicotinic acid and lovastatin in combination with cholestyramine in renal transplant patients. Mo Med 2002;99(10):580–584.

Lal SM, Ross G. Lipid lowering effects of gemfibrozil and pravastatin +/− cholestyramine in diabetic renal transplant patients [abstract]. Journal of the American Society of Nephrology: JASN 1996;7(9):1915.

Landesman K A, Stozek M, Freeman NJ. Rhabdomyolysis associated with the combined use of hydroxymethylglutaryl-coenzyme A reductase inhibitors with gemfibrozil and macrolide antibiotics. Conn Med 1999;63(8):455–457.

Lanzarotto F, Panarotto B, Sorbara R, et al. Effect of long term simvastatin administration as an adjunct to ursodeoxycholic acid: evidence for a synergistic effect on biliary bile acid composition but not on serum lipids in humans. Gut 1999;44(4):552–556.

Larsen JV. Lack of adherence to lipid-lowering drug treatment. A comparison of utilization patterns in defined populations in Funen, Denmark and Bologna, Italy. Br J Clin Pharmacol 2000;(5):463–471.

Law BM. Rx for uncertainty. Does a popular cholesterol-lowering drug do what it’s supposed to do? Diabetes Forecast 2008;61(3):19.

Lee JK, Grace KA, Taylor AJ. Effect of a pharmacy care program on medication adherence and persistence, blood pressure, and low-density lipoprotein cholesterol: a randomized controlled trial. Journal of the American Medical Association 2006;296(21):2563–2571.

Lee KK, Lee VW, Chan WK, et al. Cholesterol goal attainment in patients with coronary heart disease and elevated coronary risk: results of the Hong Kong hospital audit study. Value Health 2008;11 Suppl 1:S91–S98.

Leibovitz E, Harats D, Gavish D. Efficacy of atorvastatin in treating high risk patients to reach low density lipoprotein-cholesterol goals: The treat to target (TTT-Israel) study. Israel Medical Association Journal: Imaj 2002;4(6):407–410.

Leitersdorf E, Muratti EN, Eliav O, et al. Efficacy and safety of triple therapy (fluvastatin-bezafibrate-cholestyramine) for severe familial hypercholesterolemia. Am J Cardiol 1995;76(2):84A–88A.

Leren TP, Hjermann I, Berg K, et al. Effects of lovastatin alone and in combination with cholestyramine on serum lipids and apolipoproteins in heterozygotes for familial hypercholesterolemia. Atherosclerosis 1988;73(2–3):135–141.

Leren TP, Hjermann I, Foss OP, et al. Long-term effect of lovastatin alone and in combination with cholestyramine on lipoprotein (a) level in familial hypercholesterolemic subjects. Clin Investig 1992;70(8):711–718.

Leung N, Hegele RA, Lewis GF. Rapid development of massive tendon xanthomas following highly active antiretroviral therapy. Ann Intern Med 2002;137(7):624.

Levantesi G, Scarano M, Marfisi R, et al. Meta-analysis of effect of statin treatment on risk of sudden death. Am J Cardiol 2007;100(11):1644–1650.

Levy DR, Pearson TA. Combination niacin and statin therapy in primary and secondary prevention of cardiovascular disease. Clin Cardiol 2005;28(7):317–320.

Lewington S, Whitlock G, Clarke R, et al. Blood cholesterol and vascular mortality by age, sex, and blood pressure: a meta-analysis of individual data from 61 prospective studies with 55,000 vascular deaths. Lancet 2007;370(9602):1829–1839.

Liem A, Reynierse-Buitenwerf GH, Zwinderman AH, et al. Secondary prevention with folic acid: effects on clinical outcomes. J Am Coll Cardiol 2003;41(12):2105–2113.

Lin T-H, Voon W-C, Yen H-W, et al. Randomized comparative study of the effects of treatment with once-daily, niacin extended-release/lovastatin and with simvastatin on lipid profile and fibrinolytic parameters in Taiwan. Kaohsiung J Med Sci 2006;22(6):257–265.

Lind S, Olsson AG, Eriksson M, et al. Autosomal recessive hypercholesterolaemia: normalization of plasma LDL cholesterol by ezetimibe in combination with statin treatment. J Intern Med 2004;256(5):406–412.

Linnebur SA, Capell WH, Saseen JJ, et al. Plant sterols added to combination statin and colesevelam hydrochloride therapy failed to lower low-density lipoprotein cholesterol concentrations. Journal of Clinical Lipidology 2007;1(6):626–633.

Lintott CJ, Scott RS, Nye ER, et al. Simvastatin (MK 733): an effective treatment for hypercholesterolemia. Australian & New Zealand Journal of Medicine 1989;19(4):317–320.

Lintott CJ, Scott RS, Sharpe DN, et al. Treatment of primary hypercholesterolaemia with simvastatin. New Zealand multicentre evaluation. Med J Aust 1991;155(7):433–436.

London SF, Gross KF, Ringel SP. Cholesterol-lowering agent myopathy (CLAM). Neurology 1991;41(7):1159–1160.

Lucek DM, Coleman CI. The impact of statin use on the mortality of patients with bacteremia [review] [14 refs]. Conn Med 2007;71(7):409–412.

Lukiw WJ. Emerging amyloid beta (Ab) peptide modulators for the treatment of Alzheimer’s disease (AD) [review] [117 refs]. Expert Opin Emerg Drugs 2008;13(2):255–271.

Mabuchi H, Koizumi J, Kajinami K. Clinical efficacy and safety of cerivastatin in the treatment of heterozygous familial hypercholesterolemia. Am J Cardiol 1998;82(4B):52J–55J.

Magill-Lewis J. Cover story: One-Two Punch. Drug Topics 2004;148(9):30.

Maher VM, Gallagher JJ, Thompson GR, et al. Response to cholesterol-lowering drugs in familial defective apolipoprotein B-100. Atherosclerosis 1991;91(1–2):73–76.

Malloy MJ, Kane JP, Kunitake ST, et al. Complementarity of colestipol, niacin, and lovastatin in treatment of severe familial hypercholesterolemia. Ann Intern Med 1987;107(5):616–623.

Mancini M, Mariani M, Paoletti R, et al. Fluvastatin (F) and bezafibrate (B) in monotherapy and in combination in CAD patients with mixed hyperlipidemia: the FACT study. Atheroscler Suppl 1999;145(1):S4.

Mandema JW, Hermann D, Wang W, et al. Model-based development of gemcabene, a new lipid-altering agent. AAPS PharmSci 2005;7(3):10p.

Manfredi R, Calza L, Chiodo F. Prolonged statin administration does not act on the cell-mediated immunity of HIV-infected dyslipidemic patients treated with a steady and effective highly active antiretroviral therapy. A two-year prospective study of statin versus fibrate administration. J Biol Regul Homeost Agents 2006;20(1–2):1–9.

Mantel-Teeuwisse AK, Klungel OH, Herings RM, et al. Myopathy due to statin/fibrate use in the Netherlands. Ann Pharmacother 2002;36(12):1957–1960.

Marant C, Romon I, Fosse S, et al. French medical practice in type 2 diabetes: the need for better control of cardiovascular risk factors. Diabetes Metab 2008; 34(1):38–45.

Marchioli R, Marfisi RM, Borrelli G, et al. Efficacy of n-3 polyunsaturated fatty acids according to clinical characteristics of patients with recent myocardial infarction: insights from the GISSI-Prevenzione trial. J Cardiovasc Med (Hagerstown ) 2007;8(SUPPL 1):S34–S37.

Mark L, Dani G, Fazekas O, et al. Effects of ezetimibe on lipids and lipoproteins in patients with hypercholesterolemia and different apolipoprotein E genotypes. Current Medical Research & Opinion 2007;23(7):1541–1548.

Marsa Carretero M, Alos Manrique C, Valles Callol JA. Rhabdomyolysis associated with cerivastatin plus gemfibrozil combined regimen. Br J Gen Pract 2002;52(476):235–236.

Martin JE, Cavanaugh TM, Trumbull L, et al. Incidence of adverse events with HMG-CoA reductase inhibitors in liver transplant patients. Clin Transplant 2008;22(1):113–119.

Martin PD, Dane AL, Schneck DW, et al. An open-label, randomized, three-way crossover trial of the effects of coadministration of rosuvastatin and fenofibrate on the pharmacokinetic properties of rosuvastatin and fenofibric acid in healthy male volunteers. Clin Ther 2003;25(2):459–471.

Martin-Ventura JL, Blanco-Colio LM, Gomez-Hernandez A, et al. Intensive treatment with atorvastatin reduces inflammation in mononuclear cells and human atherosclerotic lesions in one month. Stroke 2005;36(8):1796–1800.

Masana L, Villoria J, Sust M, et al. Treatment of type IIb familial combined hyperlipidemia with the combination pravastatin-piperazine sultosilate. Eur J Pharmacol 2004;496(1–3):205–212.

Matthan NR, Giovanni A, Schaefer EJ, et al. Impact of simvastatin, niacin, and/or antioxidants on cholesterol metabolism in CAD patients with low HDL. J Lipid Res 2003;44(4):800–806.

Maxa JL, Melton LB, Ogu CC, et al. Rhabdomyolysis after concomitant use of cyclosporine, simvastatin, gemfibrozil, and itraconazole. Ann Pharmacother 2002;36(5):820–823.

May HT, Muhlestein JB. Reduction of inflammatory biomakers through the use of hyperlipidemia drugs in patients with diabetes. Cardiology Review 2007;24(4):25–27.

Mayer O, Simon J, Holubec L, et al. Fibrate treatment and prevalence risk of mild hyperhomocysteinaemia in clinical coronary heart disease patients. European Journal of Cardiovascular Prevention & Rehabilitation 2004;11(3):244–249.

McDonald KB, Garber BG, Perreault MM. Pancreatitis associated with simvastatin plus fenofibrate. Ann Pharmacother 2002;36(2):275–279.

McDougall C, Stanley A, Sattar N, et al. Severe hypertriglyceridaemia with splenomegaly in type 2 diabetes. British Journal of Diabetes and Vascular Disease 2003;3(3):227–278.

McGoldrick C, Leen CL. The management of dyslipidaemias in antiretroviral-treated HIV infection: a systematic review [review] [47 refs]. HIV Med 2007;8(6):325–334.

McInnes C, McAlpine C, Walters M. Effect of gender on stroke management in Glasgow. Age Ageing 2008;37(2):220–222.

McKelvie PA, Dennett X. Myopathy associated with HMG-CoA reductase inhibitors (statins): a series of 10 patients and review of the literature. J Clin Neuromuscul Dis 2002;3(4):143–148.

McKenney JM. Effect of drugs on high-density lipoprotein. Journal of Clinical Lipidology 2007;1(1):74–87.

McKenney J, Ballantyne CM, Feldman TA, et al. LDL-C goal attainment with ezetimibe plus simvastatin coadministration vs atorvastatin or simvastatin monotherapy in patients at high risk of CHD. Medgenmed [Computer File]: Medscape General Medicine 2005;7(3):3.

McNamara KSP. Changes in the management of acute myocardial infarction in Southern Tasmania. J Clin Pharm Ther 2000;(2):111–118.

Meade LT. Barriers to achieving LDL cholesterol goals. U 2007; S. Pharmacist. 32(3):66–71.

Meagher EA. A 60-year-old man with the metabolic syndrome. Advanced Studies in Medicine 2005;5(6A):S518.

Melani L, Mills R, Hassman D, et al. Erratum: Efficacy and safety of ezetimibe coadministered with pravastatin in patients with primary hypercholesterolemia: A prospective, randomized, double-blind trial (European Heart Journal (2003) 24:8 (717–728)). Eur Heart J 2003;24(14):1381.

Melenovsky V, Malik J, Wichterle D, et al. Comparison of the effects of atorvastatin or fenofibrate on nonlipid biochemical risk factors and the LDL particle size in subjects with combined hyperlipidemia. Am Heart J 2002;144(4):E6.

Melenovsky V, Wichterle D, Simek J, et al. Effect of atorvastatin and fenofibrate on autonomic tone in subjects with combined hyperlipidemia. Am J Cardiol 2003;92(3):337–341.

Melroe NH, Kopaczewski J, Henry K, et al. Intervention for hyperlipidemia associated with protease inhibitors [erratum appears in J Assoc Nurses AIDS Care 1999 Sep-Oct;10(5):109]. J Assoc Nurses AIDS Care 1999;10(4):55–69.

Messerli FH, Pinto L, Tang SS, et al. Impact of systemic hypertension on the cardiovascular benefits of statin therapy—a meta-analysis. Am J Cardiol 2008;101(3):319–325.

Meyers CD, McCarren M, Wong ND, et al. Baseline achievement of lipid goals and usage of lipid medications in patients with diabetes mellitus (from the Veterans Affairs Diabetes Trial). Am J Cardiol 2006;98(1):63–65.

Meyers CD, Moon YS, Ghanem H, et al. Type of preexisting lipid therapy predicts LDL-C response to ezetimibe. Ann Pharmacother 2006;40(5):818–823.

Miller M. Optimal treatment of dyslipidemia in high-risk patients: intensive statin treatment or combination therapy? [see comment] [review] [23 refs]. Prev Cardiol 2007;10(1):31–35.

Miner M, Billups KL. Erectile dysfunction and dyslipidemia: relevance and role of phosphodiesterase type-5 inhibitors and statins [review] [99 refs]. J Sex Med 2008; 5(5):1066–1078.

Minhas R, Cooper A, Walsh JD, et al. Evidence based secondary prevention following a myocardial infarction (MI): The new NICE guideline. Int J Clin Pract 2007;61(10):1604–1607.

Mitka M. Cholesterol drug controversy continues. JAMA 2008;299(19):2266.

Mitka M. Controversies surround heart drug study: questions about Vytorin and trial sponsors’ conduct. JAMA 2008;299(8):885–887.

Mitka M. Therapies aim to boost “good” cholesterol. JAMA 2008;299(5):509–510.

Mohamed Q, Gillies MC, Wong TY. Management of diabetic retinopathy: A systematic review. Journal of the American Medical Association 2007;298(8):902–916.

Mohiuddin S, Pepine K, Kelly M, et al. Efficacy and Safety of a Novel Fibrate, ABT-335, in Combination with Simvastatin in Patients with Mixed Dyslipidemia: a Phase 3 Study [ACC abstract 1021–223]. JACC 2008; 51(suppl 1):A327.

Molgaard J, von Schenck H, Olsson AG. Comparative effects of simvastatin and cholestyramine in treatment of patients with hypercholesterolaemia. Eur J Clin Pharmacol 1989;36(5):455–460.

Molgaard J, Warjerstam-Elf S, Olsson AG. Efficacy and safety of simvastatin for high-risk hypercholesterolemia. Am J Cardiol 1999;83(7):1043–1048.

Mood GR, Bavry AA, Roukoz H, et al. Meta-analysis of the role of statin therapy in reducing myocardial infarction following elective percutaneous coronary intervention. Am J Cardiol 2007;100(6):919–923.

Moon YS, Kashyap ML. Niacin extended-release/lovastatin: combination therapy for lipid disorders [review] [82 refs]. Expert Opin Pharmacother 2002;3(12):1763–1771.

Moore JD. Successful treatment with colesevelam HCl and pravastatin in a patient previously hospitalised with severe normal CPK myopathy on introduction of simvastatin. Clin Drug Investig 2005;25(6):417–420.

Morgan TO, Anderson A, Morgan O, et al. Effect of pravastatin, cholestyramine or their combination in the treatment of hypercholesterolaemia in elderly hypertensive patients. Clin Drug Investig 1995;9(6):314–323.

Moro J, Almenar L, Martinez-Dolz L, et al. Ezetimibe in heart transplantation: Initial experience. Transplant Proc 2007;39(7):2389–2392.

Movahed MR, Samsamsharaiat SA. Reproducible tendinitis-like symptoms related to statin therapy. J Clin Rheumatol 2006;12(6):320–321.

Muck W, Ritter W, Frey R, et al. Influence of cholestyramine on the pharmacokinetics of cerivastatin. International Journal of Clinical Pharmacology & Therapeutics 1997;35(6):250–254.

Muls E, Hofmans E, Droussin AM, et al. Sequential management of hypercholesterolaemia with a fibrate and simvastatin. The Belgian general practitioners’ trial. Clin Drug Investig 1995;9(2):116–126.

Muratti EN, Peters TK, Leitersdorf E. Fluvastatin in familial hypercholesterolemia: a cohort analysis of the response to combination treatment. Am J Cardiol 1994;73(14):30D–38D.

Murdoch D, Scott LJ. Ezetimibe/simvastatin: A review of its use in the management of hypercholesterolemia. American Journal of Cardiovascular Drugs 2004;4(6):405–422.

Murdock DK, Jansen D, Juza RM, et al. Benefit of adding pioglitazone to statin therapy in non-diabetic patients with the metabolic syndrome. WMJ 2006;105(5):22–25.

Murdock DK, Murdock AK, Murdock RW, et al. Long-term safety and efficacy of combination gemfibrozil and HMG-CoA reductase inhibitors for the treatment of mixed lipid disorders. Am Heart J 1999;138(1 Pt 1):151–155.

Nakagomi-Hagihara R, Nakai D, Tokui T. Inhibition of human organic anion transporter 3 mediated pravastatin transport by gemfibrozil and the metabolites in humans. Xenobiotica 2007;37(4):416–426.

Nakamura T, Kodama Y, Takano H, et al. Increase in circulating levels of adiponectin after treatment with statin and fibrate in patients with coronary artery disease and hyperlipidemia. Atherosclerosis 2007;193(2):449–451.

Negredo E, Molto J, Puig J, et al. Ezetimibe, a promising lipid-lowering agent for the treatment of dyslipidaemia in HIV-infected patients with poor response to statins. Int J STD AIDS 2006;20(17):2159–2164.

Neuman MP, Neuman HR, Neuman J. Significant increase of high-density lipoprotein2-cholesterol under prolonged simvastatin treatment. Atherosclerosis 1991;91(Suppl):S11–S19.

Newby LK. Long term use of eicosapentaenoic acid reduced major coronary events in hypercholesterolaemia. Evidence-Based Medicine 2007;12(5):136.

Newman CB, Palmer G, Silbershatz H, et al. Safety of atorvastatin derived from analysis of 44 completed trials in 9,416 patients [see comment]. Am J Cardiol 2003;92(6):670–676.

Nissen SE. Courage under fire: what is the optimal approach to initial treatment of stable angina? Curr Cardiol Rep 2008;10(2):79–80.

Nissen SE. ENHANCE and ACCORD: controversy over surrogate end points. Curr Cardiol Rep 2008;10(3):159–161.

Nitta K, Akiba T, Nihei H. Colestimide co-administered with atorvastatin attenuates the progression of vascular calcification in haemodialysis patients. Nephrology Dialysis Transplantation 2004;19(8):2156.

Nozue T, Nohara A, Higashikata T, et al. Additive effects of another kind of HMG-CoA reductase inhibitor with different pharmacokinetics in the treatment of heterozygous familial hypercholesterolemia. Atherosclerosis 2000;153(2):525–526.

Nungaray N, Arriola M, Gutierrez MJ, et al. Rapamycin at six years can exhibit normal renal function without proteinuria or neoplasia after renal transplantation. A single-center experience. Transplant Proc 2005;37(9):3727–3728.

Ofori B, Rey. Risk of congenital anomalies in pregnant users of statin drugs. Br J Clin Pharmacol 2007;64(4):496–509.

Oldemeyer JB, Lund RJ, Koch M, et al. Rhabdomyolysis and acute renal failure after changing statin-fibrate combinations. Cardiology 2000;94(2):127–128.

Olson KL, Rasmussen J, Sandhoff BG, et al. Lipid management in patients with coronary artery disease by a clinical pharmacy service in a group model health maintenance organization. Arch Intern Med 2005;165(1):49–54.

Omar MA, Wilson JP. FDA adverse event reports on statin-associated rhabdomyolysis [review] [35 refs]. Ann Pharmacother 2002;36(2):288–295.

O’Neill FH, Patel DD, Knight BL, et al. Determinants of variable response to statin treatment in patients with refractory familial hypercholesterolemia. Arterioscler Thromb Vasc Biol 2001;21(5):832–837.

O’Regan C, Wu P, Arora P, et al. Statin therapy in stroke prevention: a meta-analysis involving 121,000 patients [review] [69 refs]. Am J Med 2008; 121(1):24–33.

Orlando R, Azzalini L, Orando S, et al. Bile acids for non-alcoholic fatty liver disease and/or steatohepatitis. Cochrane Database Syst Rev 2007;(1).

Ose L, Reyes R, Johnson-Levonas AO, et al. Effects of ezetimibe/simvastatin on lipoprotein subfractions in patients with primary hypercholesterolemia: an exploratory analysis of archived samples using two commercially available techniques. Clin Ther 2007; 29(11):2419–2432.

Ozdemir O, Boran M, Gokce V, et al. A case with severe rhabdomyolysis and renal failure associated with cerivastatin-gemfibrozil combination therapy—a case report. Angiology 2000;51(8):695–697.

Pan HY, DeVault AR, Swites BJ, et al. Pharmacokinetics and pharmacodynamics of pravastatin alone and with cholestyramine in hypercholesterolemia. Clinical Pharmacology & Therapeutics 1990;48(2):201–207.

Panichi V, Manca-Rizza G, Paoletti S, et al. Safety and effects on the lipid and C-reactive protein plasma concentration of the association of ezetimibe plus atorvastatin in renal transplant patients treated by cyclosporine-A: a pilot study. Biomed Pharmacother 2006;60(5):249–252.

Papadakis JA, Ganotakis ES, Jagroop IA, et al. Statin + fibrate combination therapy fluvastatin with bezafibrate or ciprofibrate in high risk patients with vascular disease [see comment]. Int J Cardiol 1999;69(3):237–244.

Pappu AS, Illingworth DR. Contrasting effects of lovastatin and cholestyramine on low-density lipoprotein cholesterol and 24-hour urinary mevalonate excretion in patients with heterozygous familial hypercholesterolemia. Journal of Laboratory & Clinical Medicine 1989;114(5):554–562.

Paragh G, Mark L, Zamolyi K, et al. Lipid-modifying therapy and attainment of cholesterol goals in Hungary: the return on expenditure achieved for lipid therapy (REALITY) study. Clinical Drug Investigation 2007;27(9):647–660.

Parini P, Gustafsson U, Davis MA, et al. Cholesterol synthesis inhibition elicits an integrated molecular response in human livers including decreased ACAT2. Arterioscler Thromb Vasc Biol 2008;28(6):1200–1206.

Pasternak RC, Brown LE, Stone PH, et al. Effect of combination therapy with lipid-reducing drugs in patients with coronary heart disease and “normal” cholesterol levels. A randomized, placebo-controlled trial. Harvard Atherosclerosis Reversibility Project (HARP) Study Group [see comment]. Ann Intern Med 1996;125(7):529–540.

Pattis P, Wiedermann CJ. Ezetimibe-associated immune thrombocytopenia. Ann Pharmacother 2008;42(3):430–433.

Pauciullo P, Mancini M, Mariani M, et al. Treatment of mixed hyperlipidemia in coronary artery disease patients with fluvastatin and bezafibrate in monotherapy and combination. Atheroscler Suppl 1999;144(1):147.

Paumelle R, Staels B. Cross-talk between statins and PPARalpha in cardiovascular diseases: clinical evidence and basic mechanisms [review] [35 refs]. Trends Cardiovasc Med 2008;18(3):73–78.

Pedersen TR, Assmann G, Bassand J-P, et al. Reducing residual cardiovascular risk: The relevance of raising high-density lipoprotein cholesterol in patients on cholesterol-lowering treatment. Diabetes & Vascular Disease Research 2006;3(SUPPL. 2):S1–S12.

Penn R, Williams RX, Guha-Ray DK, et al. An open-label, crossover study of the pharmacokinetics of Insoluble Drug Delivery-MicroParticle fenofibrate in combination with atorvastatin, simvastatin, and extended-release niacin in healthy volunteers. Clin Ther 2006;28(1):45–54.

Phan BA, Chu B, Polissar N, et al. Association of high-density lipoprotein levels and carotid atherosclerotic plaque characteristics by magnetic resonance imaging [see comment]. Int J Cardiovasc Imaging 2007;23(3):337–342.

Phillips PSH. Statin-associated myopathy with normal creatine kinase levels. Ann Intern Med 2002;(7):581–585.

Pierce LR, Wysowski DK, Gross TP. Myopathy and rhabdomyolysis associated with lovastatin-gemfibrozil combination therapy [see comment]. JAMA 1990;264(1):71–75.

Pisciotta L, Fasano T, Bellocchio A, et al. Effect of ezetimibe coadministered with statins in genotype-confirmed heterozygous FH patients. Atherosclerosis 2007;194(2):e116–e122.

Pogson GW, Kindred L H, Carper B G. Rhabdomyolysis and renal failure associated with cerivastatin-gemfibrozil combination therapy [see comment]. Am J Cardiol 1999;83(7):1146.

Polonsky TS, Davidson MH. Reducing the residual risk of 3-hydroxy-3-methylglutaryl coenzyme a reductase inhibitor therapy with combination therapy [review] [45 refs]. Am J Cardiol 2008;101(8A):27B–35B.

Poynter JN, Gruber SB, Higgins PD, et al. Statins and the risk of colorectal cancer [see comment]. N Engl J Med 2005;352(21):2184–2192.

Pratipanawatr T, Rawdaree P, Chetthakul T, et al. Thailand Diabetes Registry Project: Current status of dyslipidemia in Thai diabetic patients. J Med Assoc Thai 2006;89(Suppl 1):S60–S65.

Pullatt RC, Gadarla MR, Karas RH, et al. Tendon rupture associated with simvastatin/ezetimibe therapy. Am J Cardiol 2007;100(1):152–153.

Punthakee Z, Scully LJ, Guindi MM, et al. Liver fibrosis attributed to lipid lowering medications: two cases [see comment]. J Intern Med 2001;250(3):249–254.

Puthenparumpil JJ, Keough-Ryan T, Kiberd M, et al. Treatment of hypercholesterolemia with ezetimibe in the kidney transplant population. Transplant Proc 2005;37(2):1033–1035.

Quarta CC, Potena L, Grigioni F, et al. Safety and efficacy of ezetimibe with low doses of simvastatin in heart transplant recipients. J Heart Lung Transplant 2008;27(6):685–688.

Raal F, Schamroth C, Patel J, et al. A multicentre, open-label, observational local study to evaluate the low-density lipoprotein cholesterol-lowering effect of ezetimibe as prescribed in daily routine practice in the South African population. Cardiovasc 2007;18(5):325–329.

Rafeiyian S, Mojtahedzadeh S, Hekmat M, et al. Supravalvular and valvular aortic stenosis in heterozygous familial hypercholesterolemia. Medical Principles & Practice 2007;16(4):315–317.

Rafter N, Connor J, Hall J, et al. Cardiovascular medications in primary care: treatment gaps and targeting by absolute risk. N Z Med J 2005;118(1223):U1676.

Raghavan VA. First-line therapies for lowering triglyceride levels [comment]. Am Fam Physician 2008;77(4):416–418.

Rajagopalan S, Vieira JL, Alemao E, et al. The impact of lipid-lowering treatment patterns on LDL-C reduction and goal attainment in secondary prevention in Germany. Cancer Prev Control 2006;2(1):15–26.

Ranki A. Bexarotene combination therapy for patients with Sezary syndrome. Dermatol Clin 2008;26 Suppl 1:55–57.

Ratz Bravo AE, Tchambaz L, Krahenbuhl-Melcher A, et al. Prevalence of potentially severe drug-drug interactions in ambulatory patients with dyslipidaemia receiving HMG-CoA reductase inhibitor therapy. Drug Saf 2005;28(3):263–275.

Razzolini R, Tarantini G, Ossena G, et al. Non-cardiovascular mortality, low-density lipoprotein cholesterol and statins: a meta-regression analysis. Cardiology 2008;109(2):110–116.

Reaven P, Witztum JL. Lovastatin, nicotinic acid, and rhabdomyolysis. Ann Intern Med 1988;109(7):597–598.

Rembold CM. To statin or to non-statin in coronary disease—considering absolute risk is the answer [review] [30 refs]. Atherosclerosis 2007;195(1):1–6.

Remick J, Weintraub H, Setton R, et al. Fibrate therapy: an update [review] [96 refs]. Cardiol Rev 2008;16(3):129–141.

Reyderman L, Kosoglou T, Boutros T, et al. Pharmacokinetic interaction between ezetimibe and lovastatin in healthy volunteers. Current Medical Research & Opinion 2004;20(9):1493–1500.

Robins DN. Case reports: alopecia universalis: hair growth following initiation of simvastatin and ezetimibe therapy. J Drugs Dermatol 2007;6(9):946–947.

Robinson JG, Davidson M. Is it over for ezetimibe? Expert Rev Cardiovasc Ther 2008;6(6):781–783.

Robinson JG, Davidson MH, Shah A, et al. Efficacy and safety of ezetimibe and ezetimibe plus statin therapy in patients aged under 65, 65–74 and 75 years and older. Aging Health 2007;3(6):691–705.

Rodenburg J, Wiegman A, Vissers MN, et al. A boy with autosomal recessive hypercholesterolaemia. Neth J Med 2004;62(3):89–93.

Roggla G, Fasan M, Kapiotis S. Treating hypertriglyceridemia [comment]. CMAJ 2007;177(6):603–605.

Ronaldson KJ, O’Shea JM, Boyd IW. Risk factors for rhabdomyolysis with simvastatin and atorvastatin. Drug Saf 2006;29(11):1061–1067.

Rondina MT, Zebrack JS. Achieving National Cholesterol Education Program goals in coronary artery disease. Prev Cardiol 2005;8(1):18–22.

Rosenberg JM, Cicero LA, Nathan JP, et al. What are the current and emerging strategies to improve low HDL-C levels? Drug Topics 2004;148(21).

Rosenson RS, Frauenheim WA. Safety of combined pravastatin-gemfibrozil therapy.[see comment]. Am J Cardiol 1994;74(5):499–500.

Rosenson RS. Gemfibrozil-lovastatin-associated myalgia [comment]. Am J Cardiol 1993;71(5):497.

Roze S, Ferrieres J, Bruckert E, et al. Cost-effectiveness of raising HDL cholesterol by adding prolonged-release nicotinic acid to statin therapy in the secondary prevention setting: a French perspective. Int J Clin Pract 2007;61(11):1805–1811.

Rustemeijer C, Schouten JA, Voerman HJ, et al. Pravastatin compared to bezafibrate in the treatment of dyslipidemia in insulin-treated patients with type 2 diabetes mellitus. Diabetes/Metabolism Research Reviews 2000;16(2):82–87.

Ryan MJ, Gibson J, Simmons P, et al. Effectiveness of aggressive management of dyslipidemia in a collaborative-care practice model. Am J Cardiol 2003;91(12):1427–1431.

Sacks FMP. Effect on coronary atherosclerosis of decrease in plasma cholesterol concentrations in normocholesterolaemic patients. Lancet 1994;(8931):1182–1186.

Saku K, Zhang B, Hirata K, et al. Combined therapy with probucol and pravastatin in hypercholesterolaemia. One year follow-up study. Eur J Clin Pharmacol 1993;44(6):535–539.

Sampalis JS, Bissonnette S, Habib R, et al. Reduction in estimated risk for coronary artery disease after use of ezetimibe with a statin. Ann Pharmacother 2007;41(9):1345–1351.

Sandset PM, Lund H, Norseth J, et al. Treatment with hydroxymethylglutaryl-coenzyme A reductase inhibitors in hypercholesterolemia induces changes in the components of the extrinsic coagulation system. Arteriosclerosis & Thrombosis 1991;11(1):138–145.

Sanllehy C, Casals E, Rodriguez-Villar C, et al. Lack of interaction of apolipoprotein E phenotype with the lipoprotein response to lovastatin or gemfibrozil in patients with primary hypercholesterolemia. Metabolism: Clinical & Experimental 1998;47(5):560–565.

Sarawate CA, Cziraky MJ, Stanek EJ, et al. Achievement of optimal combined lipid values in a managed care setting: is a new treatment paradigm needed? Clin Ther 2007;29(1):196–209.

Savelieva I, Camm J. Anti-arrhythmic drug therapy for atrial fibrillation: current anti-arrhythmic drugs, investigational agents, and innovative approaches [review] [107 refs]. Europace 2008;10(6):647–665.

Sbarouni E, Kyriakides ZS, Kremastinos DT. The effect of hormone replacement therapy and simvastatin on plasma homocysteine. Journal of Women’s Health 2005;14(2):154–158.

Schectman G, Wolff N, Byrd JC, et al. Physician extenders for cost-effective management of hypercholesterolemia [see comment]. J Gen Intern Med 1996;11(5):277–286.

Schedlbauer A, Schroeder K, Fahey T. How can adherence to lipid-lowering medication be improved? A systematic review of randomized controlled trials. Fam Pract 2007;24(4):380–387.

Schiff GD, Keehr LM, Sai TT, et al. High rates of adverse effects and patient unawareness of withdrawn lipid-lowering drug combination in a public hospital clinic [see comment]. Pharmacoepidemiology & Drug Safety 2002;11(8):643–645.

Schmidt HH, Tietge UJ, Buettner J, et al. Liver transplantation in a subject with familial hypercholesterolemia carrying the homozygous p.W577R LDL-receptor gene mutation. Clin Transplant 2008;22(2):180–184.

Schneck DW, Birmingham BK, Zalikowski JA, et al. The effect of gemfibrozil on the pharmacokinetics of rosuvastatin. Clinical Pharmacology & Therapeutics 2004;75(5):455–463.

Schweiger T, Hawkins D. Long-term care of the post-MI patient. Drug Topics 2006;150(12)

Sconce EA, Khan TI, Daly AK, et al. The impact of simvastatin on warfarin disposition and dose requirements. J Thromb Haemost 2006;4(6):1422–1424.

Scripture CD, Pieper JA. Clinical pharmacokinetics of fluvastatin. Clin Pharmacokinet 2001;40(4):263–281.

Segura T, Calleja S, Jordan J. Recommendations and treatment strategies for the management of acute ischemic stroke [review] [97 refs]. Expert Opin Pharmacother 2008;9(7):1071–1085.

Sellner J, Greeve I, Findling O, et al. Atorvastatin does not alter serum levels of sCD95 and sCD95L in multiple sclerosis. Clin Exp Immunol 2008;152(2):280–284.

Sellner J, Greeve I, Leib SL, et al. Atorvastatin does not alter interferon Beta-induced changes of serum matrix metalloproteinase 9 and tissue inhibitor of metalloproteinase 1 in patients with multiple sclerosis. Arch Neurol 2008;65(5):672–674.

Shafiq N, Bhasin B, Pattanaik S, et al. A meta-analysis to evaluate the efficacy of statins in children with familial hypercholesterolemia. Int J Clin Pharmacol Ther 2007;45(10):548–555.

Shammas NW, Kapalis MJ, Deckert J, et al. Effectiveness of statin-gemfibrozil combination therapy in patients with mixed hyperlipidemia: experience of a community lipid clinic and safety review from the literature. Prev Cardiol 2003;6(4):189–194.

Shanahan RL, Kerzee JA, Sandhoff BG, et al. Low myopathy rates associated with statins as monotherapy or combination therapy with interacting drugs in a group model health maintenance organization. Pharmacotherapy 2005;25(3):345–351.

Sharma M, Sharma DR, Singh V, et al. Evaluation of efficacy and safety of fixed dose lovastatin and niacinER combination in Asian Indian dyslipidemic patients: A multicentric study. Vasc Health Risk Manag 2006;2(1):87–93.

sheikh-Ali AA, Karas RH. Safety of lovastatin/extended release niacin compared with lovastatin alone, atorvastatin alone, pravastatin alone, and simvastatin alone (from the United States Food and Drug Administration adverse event reporting system). Am J Cardiol 2007;99(3):379–381.

sheikh-Ali AA, Kuvin JT, Karas RH. Risk of adverse events with fibrates. Am J Cardiol 2004;94(7):935–938.

sheikh-Ali AA, Karas RH. The safety of niacin in the US Food and Drug Administration adverse event reporting database [review] [20 refs]. Am J Cardiol 2008;101(8A):9B–13B.

Shemesh J, Koren-Morag N, Apter S, et al. Accelerated progression of coronary calcification: four-year follow-up in patients with stable coronary artery disease. Radiology 2004;233(1):201–209.

Shen GX. Lipid disorders in diabetes mellitus and current management. Current Pharmaceutical Analysis 2007;3(1):17–24.

Shepherd J, Vidt DG, Miller E, et al. Safety of rosuvastatin: update on 16,876 rosuvastatin-treated patients in a multinational clinical trial program. Cardiology 2007;107(4):433–443.

Shepherd J. Monotherapy vs combination therapy for dyslipidemia in the elderly [review] [37 refs]. Am J Geriatr Cardiol 2008;17(2):108–113.

Shiina Y, Homma Y, Oguma T, et al. A case of familial hypercholesterolemia; secession from LDL-apheresis by the drug treatment with potent statin and resin. Tokai Journal of Experimental & Clinical Medicine 2005;30(3):149–155.

Simard C, Poirier P. Ezetimibe-associated myopathy in monotherapy and in combination with a 3-hydroxy-3-methylglutaryl coenzyme A reductase inhibitor. Can J Cardiol 2006;22(2):141–144.

Simcor: a niacin/simvastatin combination. Med Lett Drugs Ther 2008;50(1283):25–26.

Simo IE, Yakichuk JA, Ooi TC. Effect of gemfibrozil and lovastatin on postprandial lipoprotein clearance in the hypoalphalipoproteinemia and hypertriglyceridemia syndrome. Atherosclerosis 1993;100(1):55–64.

Simons LA, Celermajer DS, Sullivan D. Effects of atorvastatin or simvastatin plus cholestyramine on arterial endothelial function in primary hypercholesterolaemia. Atheroscler 1997;134(Suppl):238.

Simons LA, Levis G, Simons J. Apparent discontinuation rates in patients prescribed lipid-lowering drugs. Med J Aust 1996;164(4):208–211.

Simons LA, Symons J. Ezetimibe added to statin therapy (EASY study) - an evaluation by Australian general practitioners. Aust Fam Physician 1996;36(1–2):90–92.

Singer JB, Holdaas H, Jardine AG, et al. Genetic analysis of fluvastatin response and dyslipidemia in renal transplant recipients. J Lipid Res 2007;48(9):2072–2078.

Singh IM, Shishehbor MH, Ansell BJ. High-density lipoprotein as a therapeutic target: A systematic review. Journal of the American Medical Association 2007;298(7):786–798.

Sinzinger H, Schmid P, O’Grady J. Two different types of exercise-induced muscle pain without myopathy and CK-elevation during HMG-Co-enzyme-A-reductase inhibitor treatment. Atherosclerosis 1999;143(2):459–460.

Siqueira Carvalho AAP. Statin and fibrate associated myopathy: Study of eight patients. Arq Neuropsiquiatr 2004;(2A):257–261.

Skrha J, Stulc T, Hilgertova J, et al. Effect of simvastatin and fenofibrate on endothelium in Type 2 diabetes. Eur J Pharmacol 2004;493(1–3):183–189.

Skulas-Ray AC, West SG, Davidson MH, et al. Omega-3 fatty acid concentrates in the treatment of moderate hypertriglyceridemia [review] [60 refs]. Expert Opin Pharmacother 2008;9(7):1237–1248.

Sleilati GG, Leff T, Bonnett JW, et al. Efficacy and safety of pioglitazone in treatment of a patient with an atypical partial lipodystrophy syndrome. Endocr Pract 2007;13(6):656–661.

Smeeth L, Cook C, Chakravarthy U, et al. A case control study of age related macular degeneration and use of statins. Br J Ophthalmol 2005;89(9):1171–1175.

Smellie WSA. Hypertriglyceridaemia in diabetes. BMJ 2006;333(7581):1257–1260.

Smith DA. New trends in lipid management: Eight cases to consider. Mt Sinai J Med 2005;72(2):90–99.

Smith DH, Neutel JM, Jankelow D, et al. Bezafibrate and simvastatin (MK-733) in the treatment of primary hypercholesterolaemia. S Afr Med J 1990;Suid-Afrikaanse Tydskrif Vir Geneeskunde 77(10):500–503.

Solfrizzi V, Capurso C, Colacicco AM, et al. Efficacy and tolerability of combined treatment with L-carnitine and simvastatin in lowering lipoprotein(a) serum levels in patients with type 2 diabetes mellitus. Atherosclerosis 2006;188(2):455–461.

Somberg JC, Molnar J. The cholesterol hypothesis: questioned? Am J Ther 2008; 15(3):292–295.

Sorokin AV, Duncan B, Panetta R, et al. Rhabdomyolysis associated with pomegranate juice consumption. Am J Cardiol 2006;98(5):705–706.

Sorokin A, Brown JL, Thompson PD. Primary biliary cirrhosis, hyperlipidemia, and atherosclerotic risk: a systematic review [review] [48 refs]. Atherosclerosis 2007;194(2):293–299.

Spence JD, Munoz CE, Hendricks L, et al. Pharmacokinetics of the combination of fluvastatin and gemfibrozil. Am J Cardiol 1995;76(2):80A–83A.

Spieker LE, Karadag B, Binggeli C, et al. Rapid progression of atherosclerotic coronary artery disease in patients with human immunodeficiency virus infection. Heart Vessels 2005;20(4):171–174.

Spieker LE, Noll G, Hannak M, et al. Efficacy and tolerability of fluvastatin and bezafibrate in patients with hyperlipidemia and persistently high triglyceride levels. J Cardiovasc Pharmacol 2000;35(3):361–365.

Sposito AC, Caramelli B, Fonseca FAH, et al. IV Brazilian guideline for dyslipidemias and prevention of atherosclerosis. International Journal of Atherosclerosis 2007;2(3):171–188.

Stang P, Morris L, Kempf J, et al. The coprescription of contraindicated drugs with statins: continuing potential for increased risk of adverse events. Am J Ther 2007;14(1):30–40.

Stankler L. Unstable angina possibly induced by withdrawal of simvastatin. British Journal of Cardiology 1999;6(8):452–453.

Starck L, Lovgren-Sandblom A, Bjorkhem I. Simvastatin treatment in the SLO syndrome: a safe approach? Am J Med Genet 2002;113(2):183–189.

Statins for high-risk patients without heart disease or high cholesterol. Medical Letter on Drugs and Therapeutics 2006;48(1225):1–3.

Stefanutti C, Bucci A, Di Giacomo S, et al. Efficacy, safety and tolerability of combined low-dose simvastatin- fenofibrate treatment in primary mixed hyperlipidaemia. Clin Drug Investig 2004;24(8):465–477.

Stein EA. The lovastatin-niacin trial: effects on lipoproteins [abstract]. Arteriosclerosis and thrombosis : a journal of vascular biology. American Heart Association 1991;11(5):1458A.

Stein EA, Ose L, Retterstol K, et al. Further reduction of low-density lipoprotein cholesterol and C-reactive protein with the addition of ezetimibe to maximum-dose rosuvastatin in patients with severe hypercholesterolemia. Journal of Clinical Lipidology 2007;1(4):280–286.

Stein EA. After ENHANCE: is more LDL cholesterol lowering even better? Clin Chem 2008;54(6):940–942.

Stewart BF, Brown BG, Zhao XQ, et al. Benefits of lipid-lowering therapy in men with elevated apolipoprotein B are not confined to those with very high low density lipoprotein cholesterol. J Am Coll Cardiol 1994;23(4):899–906.

Stolk MFJ, Becx MCJM, Kuypers KC, et al. Severe hepatic side effects of ezetimibe. Clin Gastroenterol Hepatol 2006;4(7):908–911.

Stone N. Combination therapy: Its rationale and the role of ezetimibe. Eur Heart J Suppl 2002;4(J):J19–J22.

Stone PH, Lloyd-Jones DM, Kinlay S, et al. Effect of intensive lipid lowering, with or without antioxidant vitamins, compared with moderate lipid lowering on myocardial ischemia in patients with stable coronary artery disease: the Vascular Basis for the Treatment of Myocardial Ischemia Study. Circulation 2005;111(14):1747–1755.

Strippoli GF, Navaneethan SD, Johnson DW, et al. Effects of statins in patients with chronic kidney disease: meta-analysis and meta-regression of randomised controlled trials [see comment] [review] [40 refs]. BMJ 2008;336(7645):645–651.

Stroke Prevetion by Aggressive Reduction in Cholestrol Levels (SPARCL) Investigators, Karam JG, Loney-Hutchinson L, et al. High-dose atorvastatin after stroke or transient ischemic attack: The Stroke Prevention by Aggressive Reduction in Cholesterol Levels (SPARCL) Investigators. J Cardiometab Syndr 2008;3(1):68–69.

Superko HR, Block PC. Beyond statins. Acc Cardiosource Review Journal 2007; 16(12):71–75.

Taher TH, Dzavik V, Reteff EM, et al. Tolerability of statin-fibrate and statin-niacin combination therapy in dyslipidemic patients at high risk for cardiovascular events. Am J Cardiol 2002;89(4):390–394.

Tal A, Rajeshawari M, Isley W. Rhabdomyolysis associated with simvastatin-gemfibrozil therapy. South Med J 1997;90(5):546–547.

Tang E, Wong CK, Wilkins G, et al. Use of evidence-based management for acute coronary syndrome. N Z Med J 2005;118(1223):U1678.

Tardif JC, Gregoire J, L’Allier PL, et al. Effects of the acyl coenzyme A: cholesterol acyltransferase inhibitor avasimibe on human atherosclerotic lesions. Circulation 2004;110(21):3372–3377.

Taylor AJ, Lee HJ, Sullenberger LE. The effect of 24 months of combination statin and extended-release niacin on carotid intima-media thickness: ARBITER 3. Curr Med Res Opin 2006;22(11):2243–2250.

Taylor AJ. Evidence to support aggressive management of high-density lipoprotein cholesterol: implications of recent imaging trials [review] [25 refs]. Am J Cardiol 2008; 101(8A):36B–43B.

Taylor ML, Wells BJ, Smolak MJ. Statins and cancer: a meta-analysis of case-control studies. Eur J Cancer Prev 2008;17(3):259–268.

Teichholz LE. Statin-associated myopathy with normal creatine kinase levels [comment]. Ann Intern Med 2003;138(12):1008–1009.

Tenenbaum A, Fisman EZ, Motro M, et al. Optimal management of combined dyslipidemia: what have we behind statins monotherapy? [review] [133 refs]. Adv Cardiol 2008;45:127–153.

Thompson CA. Lipid-lowering study raises issues of therapy’s value. Am J Health-Syst Pharm 2008;65(7):594–595.

Tikkanen MJB. Comparison of low-dose simvastatin and gemfibrozil in the treatment of elevated plasma cholesterol. A multicenter study. Am J Med 1989;(4 A):4A-4A.

Tikkanen MJ, Bocanegra TS, Walker JF, et al. Comparison of low-dose simvastatin and gemfibrozil in the treatment of elevated plasma cholesterol. A multicenter study. The Simvastatin Study Group. Am J Med 1989;87(4A):47S–53S.

Tkac I. Treatment of dyslipidemia in patients with type 2 diabetes: Overview and meta-analysis of randomized trials. Diabetes Research and Clinical Practice 2007;78(3 SUPPL.):S23–S28.

Tomlinson B, Lan IW. Combination therapy with cerivastatin and gemfibrozil causing rhabdomyolysis: is the interaction predictable? [comment]. Am J Med 2001;110(8):669–670.

Tomlinson B, Wong SY, Lan W, et al. Effects of fluvastatin alone and in combination with gemfibrozil on lipids and glucose tolerance in resistant hyperlipidaemia. Atheroscler Suppl 1997;62.

Tovar JM, Bazaldua OV, Poursani RS. LDL levels in diabetes: How low should they go? J Fam Pract 2007;56(8):634–640.

Tribble DL, Farnier M, Macdonell G, et al. Effects of fenofibrate and ezetimibe, both as monotherapy and in coadministration, on cholesterol mass within lipoprotein subfractions and low-density lipoprotein peak particle size in patients with mixed hyperlipidemia. Metabolism 2008;57(6):796–801.

Trimble JL, Kockler DR. Statin treatment of cerebral vasospasm after aneurysmal subarachnoid hemorrhage [review] [22 refs]. Ann Pharmacother 2007;41(12):2019–2023.

Triscari J, Swanson BN, Willard DA, et al. Steady state serum concentrations of pravastatin and digoxin when given in combination. Br J Clin Pharmacol 1993;36(3):263–265.

Tsalamandris C, Panagiotopoulos S, Sinha A, et al. Complementary effects of pravastatin and nicotinic acid in the treatment of combined hyperlipidaemia in diabetic and non-diabetic patients. J Cardiovasc Risk 1994;1(3):231–239.

Turhan H, Yetkin E. What is the best choice for combination therapy in the management of dyslipidemia of metabolic syndrome? Cardiology 2006;105(3):139–140.

Unal A, Torun E, Sipahioglu MH, et al. Fenofibrate-induced acute renal failure due to massive rhabdomyolysis after coadministration of statin in two patients. Intern Med 2008;47(11):1017–1019.

Underberg JA, Hays R. Bridging the gap in treatment options for patients with hypertriglyceridemia. J Fam Pract 2007;56(12 Suppl.):S24–S31.

Usman M, Peter R. Fibrate therapy: safety considerations. Curr Opin Lipidol 2007;18(6):702–704.

Uusitupa MI, Miettinen TA, Happonen P, et al. Lathosterol and other noncholesterol sterols during treatment of hypercholesterolemia with lovastatin alone and with cholestyramine or guar gum. Arterioscler Thromb 1992;12(7):807–813.

Uusitupa M, Ebeling T, Happonen P, et al. Combination therapy with lovastatin and guar gum versus lovastatin and cholestyramine in treatment of hypercholesterolemia. J Cardiovasc Pharmacol 1991;18(4):496–503.

Van Dam M, Zwart M, de Beer F, et al. Long term efficacy and safety of atorvastatin in the treatment of severe type III and combined dyslipidaemia. Am Heart J 2002;88(3):234–238.

Van Ganse E, Laforest L, Alemao E, et al. Lipid-modifying therapy and attainment of cholesterol goals in Europe: the Return on Expenditure Achieved for Lipid Therapy (REALITY) study. Current Medical Research & Opinion 2005;21(9):1389–1399.

van Heyningen C. Drug-induced acute autoimmune hepatitis during combination therapy with atorvastatin and ezetimibe. Ann Clin Biochem 2005;42(Pt 5):402–404.

Van JT, Pan J, Wasty T, et al. Comparison of extended-release niacin and atorvastatin monotherapies and combination treatment of the atherogenic lipid profile in diabetes mellitus. Am J Cardiol 2002;89(11):1306–1308.

Van Lente F, Cornell W. Myopathy and rhabdomyolysis with lovastatin taken with gemfibrozil (II). JAMA 1990;264(23):2991–2992.

van Puijenbroek EP, Du Buf-Vereijken PW, Spooren PF, et al. Possible increased risk of rhabdomyolysis during concomitant use of simvastatin and gemfibrozil. J Intern Med 1996;240(6):403–404.

Vasudevan AR, Jones PH. Effective use of combination lipid therapy. Curr Atheroscler Rep 2006;8(1):76–84.

Vasudevan AR, Jones PH. Effective use of combination lipid therapy. Curr Cardiol Rep 2005;7(6):471–479.

Vega GL, East C, Grundy SM. Effects of combined therapy with lovastatin and colestipol in heterozygous familial hypercholesterolemia. Effects on kinetics of apolipoprotein B. Arteriosclerosis 1989;9(1 Suppl):I135–I144.

Vega GL, Grundy SM. Comparison of lovastatin and gemfibrozil in normolipidemic patients with hypoalphalipoproteinemia [see comment]. JAMA 1989;262(22):3148–3153.

Vega GL, Grundy SM. Lipoprotein responses to treatment with lovastatin, gemfibrozil, and nicotinic acid in normolipidemic patients with hypoalphalipoproteinemia. Arch Intern Med 1994;154(1):73–82.

Vega GL, Grundy SM. Management of primary mixed hyperlipidemia with lovastatin. Arch Intern Med 1990;150(6):1313–1319.

Vega GL, Grundy SM. Treatment of primary moderate hypercholesterolemia with lovastatin (mevinolin) and colestipol. JAMA 1987;257(1):33–38.

Vega GL, Vajja M, Palacio N, et al. Combination of fenofibrate plus low-dose nicotinic acid added to statin treatment in type 2 diabetes: An open-label, crossover study. Curr Ther Res Clin Exp 2006;67(5):321–333.

Vergani C, Stefanoni P. Efficacy and tolerability of gemfibrozil in hypercholesterolemic patients previously treated with simvastatin. Adv Ther 1993;10(4):189–196.

Vergoulas G, Miserlis G, Solonaki F, et al. Combined treatment of hypercholesterolemia of renal transplant allograft recipients with fluvastatin and gemfibrozil. Transpl Int 2000;13(Suppl 1):S64–S67.

Vergouwen MD, De Haan RJ, Vermeulen M, et al. Statin treatment and the occurrence of hemorrhagic stroke in patients with a history of cerebrovascular disease [review] [27 refs]. Stroke 2008;39(2):497–502.

Viani GA, Afonso SL, Stefano EJ, et al. Adjuvant trastuzumab in the treatment of her-2-positive early breast cancer: a meta-analysis of published randomized trials. BMC Cancer 2007 Aug 8;7(153).

Visnegarwala F, Maldonado M, Sajja P, et al. Lipid lowering effects of statins and fibrates in the management of HIV dyslipidemias associated with antiretroviral therapy in HIV clinical practice. Am J Infect Control 2004;49(4):283–290.

Vittone F, Chait A, Morse JS, et al. Niacin plus simvastatin reduces coronary stenosis progression among patients with metabolic syndrome despite a modest increase in insulin resistance: A subgroup analysis of the HDL-Atherosclerosis treatment study. J Clin Lipidol 2007;1(3):203–210.

Vogt A, Kassner U, Hostalek U, et al. Correction of low HDL cholesterol to reduce cardiovascular risk: practical considerations relating to the therapeutic use of prolonged-release nicotinic acid (Niaspan) [review] [67 refs]. Int J Clin Pract 2007;61(11):1914–1921.

Vogt A, Kassner U, Hostalek U, et al. Prolonged-release nicotinic acid for the management of dyslipidemia: an update including results from the NAUTILUS study [review] [71 refs]. Vasc Health Risk Manag 2007;3(4):467–479.

Vogt A, Kassner U, Hostalek U, et al. Safety and tolerability of prolonged-release nicotinic acid combined with a statin in NAUTILUS. British Journal of Cardiology 2006;13(4):273–277.

Vuorio AF, Gylling H, Turtola H, et al. Stanol ester margarine alone and with simvastatin lowers serum cholesterol in families with familial hypercholesterolemia caused by the FH-North Karelia mutation. Arteriosclerosis, Thrombosis & Vascular Biology 2000;20(2):500–506.

Wagner AM, Jorba O, Bonet R, et al. Efficacy of atorvastatin and gemfibrozil, alone and in low dose combination, in the treatment of diabetic dyslipidemia. Journal of Clinical Endocrinology & Metabolism 2003;88(7):3212–3217.

Wakatsuki A, Okatani Y, Ikenoue N. Effects of combination therapy with estrogen plus simvastatin on lipoprotein metabolism in postmenopausal women with type IIa hypercholesterolemia. Atherosclerosis 2000;150(1):103–111.

Wald DS, Morton G, Walker K, et al. Long-term continuation on cardiovascular drug treatment in patients with coronary heart disease. Ann Pharmacother 2007;41(10):1644–1647.

Walker JF. Simvastatin: the clinical profile. Am J Med 1989;87(4A):44S–46S.

Walley T, Folino-Gallo P, Stephens P, et al. Trends in prescribing and utilization of statins and other lipid lowering drugs across Europe 1997–2003.[see comment]. Br J Clin Pharmacol 2005;60(5):543–551.

Ward S, Lloyd JM, Pandor A, et al. A systematic review and economic evaluation of statins for the prevention of coronary events [review] [406 refs]. Health Technol Assess 2007;11(14):1–160.

Weffald LA, Flach LA. Myopathy associated with atorvastatin-ezetimibe combination therapy. Pharmacotherapy 2007;27(2):309–311.

Weissgarten J, Zaidenstein R, Fishman S, et al. Rhabdomyolysis due to bezafibrate in CAPD patients. A role for dihydropyridine drugs? Perit Dial Int 1999;19(2):180–182.

Wendelhag I, Wiklund O, Wikstrand J. Intima-media thickness after cholesterol lowering in familial hypercholesterolemia. A three-year ultrasound study of common carotid and femoral arteries. Atherosclerosis 1995;117(2):225–236.

Werremeyer AB, Koo JM, Welch JM. A comparison of adverse effects of simvastatin plus gemfibrozil and atorvastatin plus gemfibrozil. Hosp Pharm 2007;42(7):631–636.

Which statin, what dose? Drug and Therapeutics Bulletin 2007;45(5):33–37.

Widimsky J, Hulinsky V, Balazovjech I, et al. Fluvastatin vs fluvastatin plus fenofibrate in CHD patients and combined hyperlipidemia. Atheroscler Suppl 1997;134:62.

Wierzbicki AS, Doherty E, Lumb PJ, et al. Efficacy of ezetimibe in patients with statin-resistant and statin-intolerant familial hyperlipidaemias. Curr Med Res Opin 2005;21(3):333–338.

Wierzbicki AS, Lumb PJ, Cheung J, et al. Fenofibrate plus simvastatin therapy versus simvastatin plus cholestyramine therapy for familial hypercholesterolaemia. QJM 1997;90(10):631–634.

Wierzbicki AS, Lumb PJ, Cheung J, et al. Fenofibrate-simvastatin therapy compared to simvastatin-resin therapy and atorvastatin for familial hypercholesterolaemia. Atheroscler Suppl 1997;134:63.

Wierzbicki AS, Lumb PJ, Semra Y, et al. Atorvastatin compared with simvastatin-based therapies in the management of severe familial hyperlipidaemias. QJM 1999;92(7):387–394.

Wierzbicki AS, Lumb PJ, Semra YK, et al. High-dose atorvastatin therapy in severe heterozygous familial hypercholesterolaemia. QJM 1998;91(4):291–294.

Wierzbicki AS. Lipid-lowering therapies in development [review] [116 refs]. Expert Opin Investig Drugs 2004;13(11):1405–1418.

Wijeratne S, Wray R, Collinson PO, et al. Hypertriglyceridaemia and malignancy. Int J Clin Pract 2005;59(2):253–255.

Wilke RA, Moore JH, Burmester JK. Relative impact of CYP3A genotype and concomitant medication on the severity of atorvastatin-induced muscle damage. Pharmacogenetics & Genomics 2005;15(6):415–421.

Wink J, Giacoppe G, King J. Effect of very-low-dose niacin on high-density lipoprotein in patients undergoing long-term statin therapy. Am Heart J 2002;143(3):514–518.

Winkler K, Ablethauser CB, Gimpelewicz C, et al. Risk reduction and tolerability of fluvastatin in patients with the metabolic syndrome: a pooled analysis of thirty clinical trials. Clin Ther 2007;29(9):1987–2000.

Wirebaugh SR, Shapiro ML, McIntyre TH, et al. A retrospective review of the use of lipid-lowering agents in combination, specifically, gemfibrozil and lovastatin. Pharmacotherapy 1992;12(6):445–450.

Witztum JL, Simmons D, Steinberg D, et al. Intensive combination drug therapy of familial hypercholesterolemia with lovastatin, probucol, and colestipol hydrochloride. Circulation 1989;79(1):16–28.

Wojtkowiak JW, Fouad F, LaLonde DT, et al. Induction of apoptosis in neurofibromatosis type 1 malignant peripheral nerve sheath tumor cell lines by a combination of novel farnesyl transferase inhibitors and lovastatin. J Pharmacol Exp Ther 2008;326(1):1–11.

Wolffenbuttel BH, Mahla G, Muller D, et al. Efficacy and safety of a new cholesterol synthesis inhibitor, atorvastatin, in comparison with simvastatin and pravastatin, in subjects with hypercholesterolemia. Neth J Med 1998;52(4):131–137.

Wolozin B, Wang SW, Li NC, et al. Simvastatin is associated with a reduced incidence of dementia and Parkinson’s disease. BMC Medicine 2007;520.

Worth JMD. A dietitian-led lipid clinic is effective. Practical Diabetes International 2006;23(5):221–226.

Yam D, Friedman J, Bott-Kanner G, et al. Omega-3 fatty acids reduce hyperlipidaemia, hyperinsulinaemia and hypertension in cardiovascular patients. Journal of Clinical & Basic Cardiology 2002;5(3):229–231.

Yamamoto A, Yamamura T, Yokoyama S, et al. Combined drug therapy—cholestyramine and compactin--for familial hypercholesterolemia. International Journal of Clinical Pharmacology, Therapy, & Toxicology 1984;22(9):493–497.

Yamanaka Y, Matsuo H, Kurachi O, et al. Effects of combined estriol/pravastatin therapy on intima-media thickness of common carotid artery in hyperlipidemic postmenopausal women. Gynecologic & Obstetric Investigation 2005;59(2):67–69.

Yates DR, Wilson RJ, Vohra RS. Peri-operative statin therapy [comment]. Anaesthesia 2008;63(6):672–673.

Yavasoglu I, Kadikoylu G, Bolaman Z. Treating hypertriglyceridemia [comment]. CMAJ 2007;177(6):603–604.

Yeshurun D, Abukarshin R, Elias N, et al. Treatment of severe, resistant familial combined hyperlipidemia with a bezafibrate-lovastatin combination. Clin Ther 1993;15(2):355–363.

Ytre-Arne K, Nordoy A. Simvastatin and cholestyramine in the long-term treatment of hypercholesterolaemia. J Intern Med 1989;226(5):285–290.

Zambon A, Brown BG, Hokanson JE, et al. Genetically determined apo B levels and peak LDL density predict angiographic response to intensive lipid-lowering therapy. J Intern Med 2006;259(4):401–409.

Zambon A, Hokanson JE, Brown BG, et al. Evidence for a new pathophysiological mechanism for coronary artery disease regression: hepatic lipase-mediated changes in LDL density. Circulation 1999;99(15):1959–1964.

Zambon D, Ros E, Rodriguez-Villar C, et al. Randomized crossover study of gemfibrozil versus lovastatin in familial combined hyperlipidemia: additive effects of combination treatment on lipid regulation. Metabolism: Clinical & Experimental 1999;48(1):47–54.

Zdrenghea D, Gligor E, Ossian V, et al. The effect of simvastatin associated with ranitidine and alcohol upon serum lipids. Rom J Intern Med 2004;42(1):143–148.

Zeman M, Zak A, Vecka M, et al. N-3 fatty acid supplementation decreases plasma homocysteine in diabetic dyslipidemia treated with statin-fibrate combination. J Nutr Biochem 2006;17(6):379–384.

Zhao XQ, Morse JS, Dowdy AA, et al. Safety and tolerability of simvastatin plus niacin in patients with coronary artery disease and low high-density lipoprotein cholesterol (The HDL Atherosclerosis Treatment Study). Am J Cardiol 2004;93(3):307–312.

Zhao XQ, Morse JS, Dowdy AA, et al. Trial finds that simvastatin plus niacin is safe in people with coronary artery disease and low HDL cholesterol. Evidence-Based Cardiovascular Medicine 2004;8(2):171–176.

Zhao XQ, Phan BA, Chu B, et al. Testing the hypothesis of atherosclerotic plaque lipid depletion during lipid therapy by magnetic resonance imaging: study design of Carotid Plaque Composition Study. Am Heart J 2007;154(2):239–246.

Ziajka PE, Reis M, Kreul S, et al. Initial low-density lipoprotein response to statin therapy predicts subsequent low-density lipoprotein response to the addition of ezetimibe. Am J Cardiol 2004;93(6):779–780.

Zimlichman E, Szyper-Kravitz M, Katz U, et al. Intensive lipid-lowering therapy: obvious benefits, possible risks. Isr Med Assoc J 2006;8(12):890–891.

### Systematic Reviews

Aldridge MA, Ito MK. Colesevelam hydrochloride: a novel bile acid-binding resin [review] [37 refs]. Ann Pharmacother 2001;35(7–8):898–907.

Anonymous. Ezetimibe: new preparation. A cholesterol-lowering drug with no clinical advantage. Prescrire Int 2004;13(73):176–179.

Backes JM, Gibson CA, Howard PA. Optimal lipid modification: the rationale for combination therapy [review] [141 refs]. Vasc Health Risk Manag 2005;1(4):317–331.

Bang LM, Goa KL. Pravastatin: a review of its use in elderly patients [review] [119 refs]. Drugs Aging 2003;20(14):1061–1082.

Birjmohun RS, Hutten BA, Kastelein JJ, et al. Increasing HDL cholesterol with extended-release nicotinic acid: from promise to practice [review] [33 refs]. Neth J Med 2004;62(7):229–234.

Cheng JW. Rosuvastatin in the management of hyperlipidemia [review] [61 refs]. Clin Ther 2004;26(9):1368–1387.

Jeu L, Cheng JW. Pharmacology and therapeutics of ezetimibe (SCH 58235), a cholesterol-absorption inhibitor [review] [87 refs]. Clin Ther 2003;25(9):2352–2387.

Kashani A, Sallam T, Bheemreddy S, et al. Review of side-effect profile of combination ezetimibe and statin therapy in randomized clinical trials [review] [31 refs]. Am J Cardiol 2008;101(11):1606–1613.

Keating GM, Croom KF. Fenofibrate: a review of its use in primary dyslipidaemia, the metabolic syndrome and type 2 diabetes mellitus [review] [194 refs]. Drugs 2007;67(1):121–153.

Kinlay S. Low-density lipoprotein-dependent and -independent effects of cholesterol-lowering therapies on C-reactive protein: a meta-analysis [see comment]. J Am Coll Cardiol 2007;49(20):2003–2009.

Langtry HD, Markham A. Fluvastatin: a review of its use in lipid disorders [erratum appears in Drugs 1999 Sep;58(3):404] [review] [107 refs]. Drugs 1999;57(4):583–606.

Law M, Rudnicka AR. Statin safety: A systematic review. Am J Cardiol 2006;97(8 Suppl 1):S52–S60.

Mauro VF, Tuckerman CE. Ezetimibe for management of hypercholesterolemia [review] [64 refs]. Ann Pharmacother 2003;37(6):839–848.

McPherson R, Frohlich J, Fodor G, et al. Canadian Cardiovascular Society position statement - recommendations for the diagnosis and treatment of dyslipidemia and prevention of cardiovascular disease. Can J Cardiol 2006;22(11):913–927.

Mikhailidis DP, Sibbring GC, Ballantyne CM, et al. Meta-analysis of the cholesterol-lowering effect of ezetimibe added to ongoing statin therapy. Curr Med Res Opin 2007;23(8):2009–2026.

Omar MA, Wilson JP, Cox TS. Rhabdomyolysis and HMG-CoA reductase inhibitors [erratum appears in Ann Pharmacother 2001 Oct;35(10):1296] [review] [109 refs]. Ann Pharmacother 2001;35(9):1096–1107.

Patel J. Dyslipidaemia in diabetes [review] [54 refs]. Clinic Evid 2006;(15):555–575.

Penzak SR, Chuck SK. Hyperlipidemia associated with HIV protease inhibitor use: pathophysiology, prevalence, risk factors and treatment [review] [72 refs]. Scand J Infect Dis 2000;32(2):111–123.

Psaty BM, Furberg CD, Ray WA, et al. Potential for conflict of interest in the evaluation of suspected adverse drug reactions: use of cerivastatin and risk of rhabdomyolysis [see comment] [review] [64 refs]. JAMA 2004;292(21):2622–2631.

Sudlow C, Lonn E, Pignone M, et al. Secondary prevention of ischaemic cardiac events [update in Clin Evid 2002 Dec;(8):129–68;PMID: 12603875] [eview] [133 refs]. Clinic Evid 2002;(7):124–160.

Thompson PD, Clarkson P, Karas RH. Statin-associated myopathy [see comment] [review] [100 refs]. JAMA 2003;289(13):1681–1690.

Verges B. Diabetic dyslipidaemia: insights for optimizing patient management [review] [89 refs]. Curr Med Res Opin 2005;21(Suppl 1):S29–S40.

Weffald LA, Flach LA. Myopathy associated with atorvastatin-ezetimibe combination therapy. Pharmacotherapy 2007;27(2):309–311.

Yim BT, Chong PH. Niacin-ER and lovastatin treatment of hypercholesterolemia and mixed dyslipidemia [review] [56 refs]. Ann Pharmacother 2003;37(1):106–115.

### Not Able To Retrieve

Al-Olah YH, Carr-Lopez S M. Rhabdomyolysis secondary to the concomitant use of simvastatin and gemfibrozil. Saudi Pharm J 2002;10(1–2):65–69.

Anonymous. Bile acid sequestrant-fibrate combination effective for mixed hyperlipidemia. Cardiol Rev 2005;22(11):6.

Anonymous. FDA approves Vytorin (ezetimibe/simvastatin) - cholesterol reduction through dual inhibition of the two sources of cholesterol in one tablet. S Afr Med J 2004;94(9):741.

Anonymous. Guidelines address management of lipid disorders associated with antiretroviral therapy. Am J Health Syst Pharm 2000;57(14):1309–1310.

Anonymous. Zocor tabs—MSD. Pharmindex 1992;34(4):5–7.

Antihypercholesterolaemic aminophosphate derivatives. Expert Opinion on Therapeutic Patents 1994;(4):453–454.

Athyros V, Papageorgiou A, Athyrou V, et al. Long term safety and efficacy of atorvastatin versus four statin-fibrate combinations on lipid profile and plasma fibrinogen in patients with familial combined hyperlipidemia. Atheroscler Suppl 1999;144(1):28.

Bagley JL. Drugs that touch the heart. American Druggist 1988;198(1):48–50.

Barber PG. Cholesterol solutions. American Druggist 1989;82(3):45–50.

Bays HE, Dujovne CA. Drug therapy for hyperlipidemia: When reducing cardiovascular risk is a priority. Postgrad Med 1992;91(5):162–193.

Berg K. Lp(a) lipoprotein and atherosclerosis. Curr Ther Res Clin Exp 1995;(4):245–251.

Bohannon NJV. Lipid metabolism in type II diabetes. Postgrad Med 1992;92(2):105–113.

Capella D, Bosch. Statins: Benefit or risk? Med Clin (Barc) 2002;(9):335–336.

Dedhia V, Munsi SC. Myopathy caused by a combination rosuvastatin and fenofibrate. J Assoc Physicians India 2007;55152–153.

First reports of adverse drug reactions (ADRs) in recent weeks. Drugs and Therapy Perspectives 2001;(13):15.

Glueck CJO. Using two-drug therapy safely for refractory mixed hyperlipidemia. Cardiology Board Review 1993;(6):56–59.

HMG-CoA reductase inhibitors. Expert Opinion on Therapeutic Patents 1996;(1):77–78.

Hsia J. Bile acid sequestrants play important role in cholesterol reduction. Cardiology Review 2002;(11 Suppl):2–3.

Issac TT, Dokainish H, Lakkis NM. Role of inflammation in initiation and perpetuation of atrial fibrillation: a systematic review of the published data [review] [65 refs]. J Am Coll Cardiol 2007;50(21):2021–2028.

Knopp RH. New approaches to cholesterol lowering: efficacy and safety [review] [37 refs]. Hospital Practice (Office Edition) 1988;23(Suppl 1):22–30.

Krahn M. Prevastatin versus gemfibrozil for primary hypercholesterolemia. Ann Intern Med 1991;114(Suppl 3):77.

Laker MF, Neely RDG. The investigation and management of dyslipidaemia: An update. Cpd Bulletin Clinical Biochemistry 2003;5(3):75–79.

Lin T-H, Voon W-C, Yen H-W, et al. Randomized comparative study of the effects of treatment with once-daily, niacin extended-release/lovastatin and with simvastatin on lipid profile and fibrinolytic parameters in Taiwan. Kaohsiung J Med Sci 2006;22(6):257–265.

Mancini GBJ. Clinical evidence for atherosclerotic lesion regression. J Drug Dev 1992;4(4):21–27.

Mann RD. Executive summary gemfibrozil. J Drug Eval: Cardiovasc Med 2002;1(1):9.

Manson JE. Treating women to new lipid goals. Cardiology Review 2002;(11 Suppl):1+4.

Mason JC. The role of statins in vascular protection. Clinical Advances in Hematology and Oncology 2007;5(5):352–354.

Merchante Alfaro AA. Novelties in the treatment of dyslipidemia in HIV-infected patients. Nutrition and Metabolic Disorders in HIV Infection 2007;6(4):1181–1187.

Mrazik TJ. Dietary and drug treatment of high blood cholesterol. American Druggist 1989;200(5):43–52.

Narain VS, Puri A, Ahuja A. 10 Years of clinical trials in diabetic patient with coronary artery disease. Journal of Internal Medicine of India 2006;9(1):20–26.

Nichols AW. Probiotics and athletic performance: A systematic review. Current Sports Medicine Reports 2007;6(4):269–273.

Oliver MA. Medical management of diabetic vascular disease. J Vasc Ultrasound 2006;30(4):199–201.

Pardo J, Romero R, Torres M, et al. Necrotizing myopathy associated with atorvastatin therapy. Acta Myol 1999;(3):74.

Pierce LR, Wysowski DK, Gross TP. Myopathy and rhabdomyolysis with lovastatin taken with gemfibrozil (Reply). JAMA 1990;264(23):2992.

Poli D, Pecci A, Noris P, et al. Peripheral arteriopathy of the lower limbs in a patient with severe congenital thrombocytopenia. Intern Emerg Med 2006;1(1):83–85.

Ross A. Questions over cholesterol’s causative role in coronary artery disease. British Journal of Cardiology 2005;12(5):338.

Rychlik R, Nelles S. Statins - A differentiated view. A systematic literature comparison of atorvastatin with fluvastatin, lovastatin, pravastatin, rosuvastatin and simvastatin. Perfusion 2004;17(9):306–315.

Shi XZ, Ye ZR. Journal of Qiqihar Medical College with low high-density lipoprotein (HDL) cholesterol and elevated low-density lipoprotein (LDL) cholesterol. Journal of Qiqihar Medical College 2002;23(6):604–605.

Shviro I, Leitersdorf E. The patient at risk: who should we be treating? [review] [25 refs]. Br J Clin Pract 1996;(Suppl 77A):24–27.

Singh S, Bahl VK. Plaque passivation: role of statins in acute coronary syndromes. Indian Heart J 2003;55(6):605–610.

Stoy DB. Diet and drug therapy for hypercholesterolemia. AAOHN J 1990;38(5):222–229.

Tsalamandris C, Panagiotopoulos S, Sinha A, et al. Complementary effects of pravastatin and nicotinic acid in the treatment of combined hyperlipidaemia in diabetic and non-diabetic patients. J Cardiovasc Risk 1994;1(3):231–239.

Van Lente F, Cornell W. Myopathy and rhabdomyolysis with lovastatin taken with gemfibrozil (II). JAMA 1990;264(23):2991–2992.

Watts GF, Burnett JR. An ABC of HDL: A paradigm shift in managing lipid disorders. Med Today 2003;4(10):44–53.

Zhou B, Teramukai S, Fukushima M. Prevention and treatment of dementia or Alzheimer’s disease by statins: a meta-analysis. Dement Geriatr Cogn Disord 2007;23(3):194–201.

### Investigational Fibrate

Goldberg A, Bays H, Ballantyne C, et al. Efficacy and Safety of a Novel fibrate, ABT-335, in Combination with Atorvastatin in Patients with Mixed Dyslipidemia; a 12-week Phase 3 Study. JACC 2008;51(Suppl 1):A327.

Jones P, Buttler S, Davidson M, et al. Efficacy and Safety of ABT-335 (Fenofibric Acid) in Combination with Rosuvastatin in Patients with Mixed Dyslipidemia: a Phase 3 Study [NLA Abstract 214]. J Clin Lipidol 2008;2(3):218.

## Excluded Studies - Evidence Synthesis

### Non-Randomized Studies

Cziraky MJ, Willey VJ, McKenney JM, et al. Statin safety: an assessment using an administrative claims database. Am J Cardiol 2006;97(8A):61C–68C.

Da Col PG, Cattin L, Valenti M, et al. Efficacy of simvastatin plus cholestyramine in the two-year treatment of heterozygous hypercholesterolemia. Curr Ther Res Clin Exp 1990;48(5):798–808.

Graham DJ, Staffa JA, Shatin D, et al. Incidence of hospitalized rhabdomyolysis in patients treated with lipid-lowering drugs. JAMA 2004;292(21):2585–2590.

Jacotot B, Banga JD, Waite R, et al. Long-term efficacy with fluvastatin as monotherapy and combined with cholestyramine (a 156-week multicenter study). French-Dutch Fluvastatin Study Group. Am J Cardiol 1995;76(2):41A–46A.

LaFleur J, Thompson CJ, Joish VN, et al. Adherence and persistence with single-dosage form extended-release niacin/lovastatin compared with statins alone or in combination with extended-release niacin. Ann Pharmacother 2006;40(7–8):1274–1279.

McClure DL, Valuck RJ, Glanz M, et al. Statin and statin-fibrate use was significantly associated with increased myositis risk in a managed care population. J Clin Epidemiol 2007;60(8):812–818.

McIvor ME, Witt JR, King HM, et al. Lipid lowering therapy is safe in the elderly: The LifeHelp 80–80 analysis. Am J Geriatr Cardiol 2000;9(5):281–285.

Molgaard J, Lundh BL, von Schenck H, et al. Long-term efficacy and safety of simvastatin alone and in combination therapy in treatment of hypercholesterolaemia. Atherosclerosis 1991;91(Suppl):S21–S28.

Schech S, Graham D, Staffa J, et al. Risk factors for statin-associated rhabdomyolysis. Pharmacoepidemiol Drug Saf 2007;16(3):352–358.

Tirkkonen T, Ryynanen A, Vahlberg T, et al. Frequency and clinical relevance of drug interactions with lovastatin and simvastatin: an observational database study. Drug Saf 2008;31(3):231–240.

### Drug(s) Not Marketed in the United States

Avisar I, Brook JG, Wolfovitz E. Atorvastatin monotherapy vs. combination therapy in the management of patients with combined hyperlipidemia. EUR 2008;19(3):203–208.

Cortellaro M, Cofrancesco E, Boschetti C, et al. Effects of fluvastatin and bezafibrate combination on plasma fibrinogen, t-plasminogen activator inhibitor and C reactive protein levels in coronary artery disease patients with mixed hyperlipidaemia (FACT study). Fluvastatin Alone and in Combination Treatment. Thromb Haemost 2000;83(4):549–53.

Kontopoulos AG, Athyros VG, Papageorgiou AA, et al. Effects of simvastatin and ciprofibrate alone and in combination on lipid profile, plasma fibrinogen and low density lipoprotein particle structure and distribution in patients with familial combined hyperlipidaemia and coronary artery disease. Coron Artery Dis 1996;7(11):843–850.

Pauciullo P, Borgnino C, Paoletti R, et al. Efficacy and safety of a combination of fluvastatin and bezafibrate in patients with mixed hyperlipidaemia (FACT study) [see comment]. Atherosclerosis 2000;150(2):429–436.

Tasaki H, Miyamoto M, Kubara T, et al. Cross-over trial of intensive monotherapy with atorvastatin and combined therapy with atorvastatin and colestimide for Japanese familial hypercholesterolemia. Circ J 2006;70(1):14–20.

### Randomized Crossover Designs - Appropriate Data Not Reported

Balestrieri GP, Maffi V, Sleiman I, et al. Fish oil supplementation in patients with heterozygous familial hypercholesterolemia. Recenti Prog Med 1996;87(3):102–105.

Hansen JB, Lyngmo V, Svensson B, et al. Inhibition of exercise-induced shortening of bleeding time by fish oil in familial hypercholesterolemia (type IIa). Arterioscler Thromb 1993;13(1):98–104.

Koh KK, Quon MJ, Han SH, et al. Additive beneficial effects of fenofibrate combined with atorvastatin in the treatment of combined hyperlipidemia. Journal of the American College of Cardiology 2005;45(10):1649–1653.

McKenney JM, Swearingen D, Di Spirito M, et al. Study of the pharmacokinetic interaction between simvastatin and prescription omega-3-acid ethyl esters. Journal of Clinical Pharmacology 2006;46(7):785–791.

Morgan TO, Anderson A, Morgan O, et al. Effect of pravastatin, cholestyramine or their combination in the treatment of hypercholesterolaemia in elderly hypertensive patients. Clin Drug Investig 1995;9(6):314–323.

Smit JW, Van Erpecum KJ, Portincasa P, et al. Effects of simvastatin and cholestyramine on bile lipid composition and gall bladder motility in patients with hypercholesterolaemia. Gut 1995;37(5):654–659.

Tasaki H, Miyamoto M, Kubara T, et al. Cross-over trial of intensive monotherapy with atorvastatin and combined therapy with atorvastatin and colestimide for Japanese familial hypercholesterolemia. Circ J 2006;70(1):14–20.

Vega GL, Ma PT, Cater NB, et al. Effects of adding fenofibrate (200 mg/day) to simvastatin (10 mg/day) in patients with combined hyperlipidemia and metabolic syndrome. American Journal of Cardiology 2003;91(8):956–986.

### Randomized Parallel, Non-Crossover Design - Analyzable Data Not Reported

Assmann G, Kannenberg F, Ramey DR, et al. Effects of ezetimibe, simvastatin, atorvastatin, and ezetimibe-statin therapies on non-cholesterol sterols in patients with primary hypercholesterolemia. Curr Med Res Opin 2008;24(1):249–259.

May HT, Anderson JL, Pearson RR, et al. Comparison of effects of simvastatin alone versus fenofibrate alone versus simvastatin plus fenofibrate on lipoprotein subparticle profiles in diabetic patients with mixed dyslipidemia (from the Diabetes and Combined Lipid Therapy Regimen study). Am J Cardiol 2008;101(4):486–489.

Reyderman, L, Kosoglou T, Cutler DL, et al. The effect of fluvastatin on the pharmacokinetics and pharmacodynamics of ezetimibe. Curr Med Res Opin 2005;21(8):1171–1179.

Weinstock RS, Goldberg RB, Guyton JR, et al. Effect of Ezetimibe/Simvastatin versus Atorvastatin on Lowering Levels of LDL-C and Non- HDL-C, Apo B and hsCRP in Patients with Type 2 Diabetes. Journal of Clinical Lipidology 2008;2(1):25–35.