# Appendix K Literature Search 2009 Update (August 2008 to May 2009) Including the Update Flow Chart and List of Included and Excluded Records

## Flow Chart

## Included Studies

Airan-Javia SL, Wolf RL, Wolfe ML, et al. Atheroprotective lipoprotein effects of a niacin-simvastatin combination compared to low- and high-dose simvastatin monotherapy. Am Heart J 2009 Apr;157(4):687–8.

Bays H, Sapre A, Taggart W, et al. Long-term (48-week) safety of ezetimibe 10 mg/day coadministered with simvastatin compared to simvastatin alone in patients with primary hypercholesterolemia. Curr Med Res Opin 2008 Oct;24(10):2953–66.

Saito Y, Yokoyama M, Origasa H, et al. Effects of EPA on coronary artery disease in hypercholesterolemic patients with multiple risk factors: sub-analysis of primary prevention cases from the Japan EPA Lipid Intervention Study (JELIS). Atherosclerosis 2008 Sep;200(1):135–40.

## Excluded Studies – Full Text Relevance

### Do Not Directly Address the Key Questions

Farmer JA. Intensive lipid lowering with simvastatin and ezetimibe in aortic stenosis (the SEAS trial). Curr Atheroscler Rep 2009 Mar;11(2):82–3.

Maccubbin D, Bays HE, Olsson AG, et al. Lipid-modifying efficacy and tolerability of extended-release niacin/laropiprant in patients with primary hypercholesterolaemia or mixed dyslipidaemia. Int J Clin Pract 2008 Dec;62(12):1959–70.

Bays HE, Maccubbin D, Meehan AG, et al. Blood pressure-lowering effects of extended-release niacin alone and extended-release niacin/laropiprant combination: a post hoc analysis of a 24-week, placebo-controlled trial in dyslipidemic patients. Clin Ther 2009 Jan;31(1):115–22.

Valdivielso P, Rioja J, Garcia-Arias C, et al. Omega 3 fatty acids induce a marked reduction of apolipoprotein B48 when added to fluvastatin in patients with type 2 diabetes and mixed hyperlipidemia: a preliminary report. Cardiovasc 2009;8:1

Rosenson RS, Pitt B. Triglycerides and cardiovascular events in ACS: the need for combined lipid-altering therapies. Nat Clin Pract Cardiovasc Med 2009 Feb;6(2):98–100.

Steg PG, Verdier JC, Carre F, et al. A randomised trial of three counselling strategies for lifestyle changes in patients with hypercholesterolemia treated with ezetimibe on top of statin therapy (TWICE). Arch Cardiovasc Dis 2008 Nov;101(11–12):723–35.

Hildemann SK, Barho C, Karmann B, et al. Sustained effects in hypercholesterolaemic patients on combined simvastatin/ezetimibe treatment: observational cohort study in clinical practice. Curr Med Res Opin 2008 Oct;24(10):2777–84.

Di SM, Morelli G, Doyle RT, et al. Effect of omega-3-acid ethyl esters on steady-state plasma pharmacokinetics of atorvastatin in healthy adults. Expert Opin Pharmacother 2008 Dec;9(17):2939–45.

Maki KC, McKenney JM, Reeves MS, et al. Effects of adding prescription omega-3 acid ethyl esters to simvastatin (20 mg/day) on lipids and lipoprotein particles in men and women with mixed dyslipidemia [erratum appears in Am J Cardiol 2008 Nov 15;102(10):1425]. Am J Cardiol 2008 Aug 15;102(4):429–33.

Domanski M, Tian X, Fleg J, et al. Pleiotropic effect of lovastatin, with and without cholestyramine, in the post coronary artery bypass graft (Post CABG) trial. Am J Cardiol 2008 Oct 15;102(8):1023–7.

Ara R, Pandor A, Tumur I, et al. Estimating the health benefits and costs associated with ezetimibe coadministered with statin therapy compared with higher dose statin monotherapy in patients with established cardiovascular disease: results of a Markov model for UK costs using data registries. Clin Ther 2008 Aug;30(8):1508–23.

Berthold HK, Laaksonen R, Lehtimaki T, et al. SREBP-1c gene polymorphism is associated with increased inhibition of cholesterol-absorption in response to ezetimibe treatment. Exp Clin Endocrinol Diabetes 2008 May;116(5):262–7.

Cramariuc D, Cioffi G, Rieck AE, et al. Low-Flow Aortic Stenosis in Asymptomatic Patients. Valvular-Arterial Impedance and Systolic Function From the SEAS Substudy. JACC Cardiovasc Imaging 2009;2(4):390–9.

de Rojas FD, De FT, Ponte A, et al. Coronary heart disease and dyslipidemia: A cross-sectional evaluation of prevalence, current treatment, and clinical control in a large cohort of Spanish high-risk patients: The

### Not Able To Retrieve

Hari KS, Rajeev E, Tharakan JA, et al. Efficacy and safety of combination of extended release niacin and atorvastatin in patients with low levels of high density lipoprotein cholesterol. Indian Heart J 2008 May;60(3):215–22.

Banerjee AK. Changing face of dyslipidemia therapy. Indian Heart Journal 2008;60(3):192–4.

Schmitz SA, O'Regan DP, Fitzpatrick J, et al. Quantitative 3T MR imaging of the descending thoracic aorta: patients with familial hypercholesterolemia have an increased aortic plaque burden despite long-term lipid-lowering therapy. J Vasc Interv Radiol 2008 Oct;19(10):1403–8.

PRINCEPS study. Prev Cardiol 2009;12(2):65–71.

Yusuf S, Lonn E, Bosch J. Lipid lowering for primary prevention. The Lancet 2009;373(9670):1152–5.

Maki KC, Lubin BC, Reeves MS, et al. Prescription omega-3 acid ethyl esters plus simvastatin 20 and 80 mg: effects in mixed dyslipidemia. Journal of Clinical Lipidology 2009;3(1):33–8.

Block JP. Limited benefit for aggressive lipid lowering with simvastatin/ezetimibe in patients with aortic stenosis; possible increased risk of cancer. Journal of Clinical Outcomes Management 2008;15(11):528+530

Criqui MH, Golomb BA. Lipid lowering: what and when to monitor. The Lancet 2008;372(9638):516–7.

## Excluded Studies - Evidence Synthesis

### Non-Randomized Studies

Derosa G, D'Angelo A, Franzetti IG, et al. Efficacy and safety of ezetimibe/simvastatin association on non-diabetic and diabetic patients with polygenic hypercholesterolemia or combined hyperlipidemia and previously intolerant to standard statin treatment. Journal of Clinical Pharmacy and Therapeutics 2009;34(3):267–76.

### Drug(s) Not Marketed in the United States

Nomura S, Inami N, Shouzu A, et al. The effects of pitavastatin, eicosapentaenoic acid and combined therapy on platelet-derived microparticles and adiponectin in hyperlipidemic, diabetic patients. Platelets 2009 Feb;20(1):16–22.

## Otherwise Eligible Records Identified in Search Update That Were Excluded from Evidence Synthesizes Because Did Not Report Clinical Outcomes or Because < 24 Weeks Duration

Mindrescu C, Gupta RP, Hermance EV, et al. Omega-3 fatty acids plus rosuvastatin improves endothelial function in South Asians with dyslipidemia. Vasc Health Risk Manag 2008;4(6):1439–47.

Goldberg AC, Bays HE, Ballantyne CM, et al. Efficacy and safety of ABT-335 (fenofibric acid) in combination with atorvastatin in patients with mixed dyslipidemia. Am J Cardiol 2009 Feb 15;103(4):515–22.

Malmstrom RE, Settergren M, Bohm F, et al. No effect of lipid lowering on platelet activity in patients with coronary artery disease and type 2 diabetes or impaired glucose tolerance. Thromb Haemost 2009 Jan;101(1):157–64.

Zhu T, Awni WM, Hosmane B, et al. ABT-335, the choline salt of fenofibric acid, does not have a clinically significant pharmacokinetic interaction with rosuvastatin in humans. J Clin Pharmacol 2009 Jan;49(1):63–71.

Liu PY, Liu YW, Lin LJ, et al. Evidence for statin pleiotropy in humans: differential effects of statins and ezetimibe on rho-associated coiled-coil containing protein kinase activity, endothelial function, and inflammation. Circulation 2009 Jan 6;119(1):131–8.

Lin TH, Voon WC, Yen HW, et al. Randomized comparative study of the effects of treatment with once-daily, niacin extended-release/lovastatin and with simvastatin on lipid profile and fibrinolytic parameters in Taiwan. Kaohsiung Journal of Medical Sciences 2006 Jun;22(6):257–65.

Mohiuddin SM, Pepine CJ, Kelly MT, et al. Efficacy and safety of ABT-335 (fenofibric acid) in combination with simvastatin in patients with mixed dyslipidemia: a phase 3, randomized, controlled study. Am Heart J 2009 Jan;157(1):195–203.

Gosai P, Liu J, Doyle RT, et al. Effect of omega-3-acid ethyl esters on the steady-state plasma pharmacokinetics of rosuvastatin in healthy adults. Expert Opin Pharmacother 2008 Dec;9(17):2947–53.

Westerweel PE, Visseren FL, Hajer GR, et al. Endothelial progenitor cell levels in obese men with the metabolic syndrome and the effect of simvastatin monotherapy vs. simvastatin/ezetimibe combination therapy. Eur Heart J 2008 Nov;29(22):2808–17.

Olijhoek JK, Hajer GR, van der GY, et al. The effects of low-dose simvastatin and ezetimibe compared to high-dose simvastatin alone on post-fat load endothelial function in patients with metabolic syndrome: a randomized double-blind crossover trial. J Cardiovasc Pharmacol 2008 Aug;52(2):145–50.

Zubaid M, Shakir DK, Bazargani N, et al. Effect of ezetimibe coadministration with simvastatin in a Middle Eastern population: a prospective, multicentre, randomized, double-blind, placebo-controlled trial. J Cardiovasc Med (Hagerstown) 2008 Jul;9(7):688–93.

Jones PH, Davidson MH, Kashyap ML, et al. Efficacy and safety of ABT-335 (fenofibric acid) in combination with rosuvastatin in patients with mixed dyslipidemia: A phase 3 study. Atherosclerosis 2009;204(1):208–15.

Farnier M, Averna M, Missault L, et al. Lipid-altering efficacy of ezetimibe/simvastatin 10/20 mg compared with rosuvastatin 10 mg in high-risk hypercholesterolaemic patients inadequately controlled with prior statin monotherapy - The IN-CROSS study. Int J Clin Pract 2009;63(4):547–59.

Insull J, W, Basile JN, et al. Efficacy and safety of combination therapy with niacin extended-release and simvastatin versus atorvastatin in patients with dyslipidemia: The SUPREME Study. Journal of Clinical Lipidology 2009;3(2):109–18.

Hajer GR, linga-Thie GM, van Vark - van der Zee, et al. The effect of statin alone or in combination with ezetimibe on postprandial lipoprotein composition in obese metabolic syndrome patients. Atherosclerosis 2009;202(1):216–24.

Hajer GR, linga-Thie GM, Van Vark-Van Der Zee, et al. Lipid-lowering therapy does not affect the postprandial drop in high density lipoprotein-cholesterol (HDL-c) plasma levels in obese men with metabolic syndrome: A randomized double blind crossover trial. Clin Endocrinol (Oxf) 2008;69(6):870–7.

Ahmed S, Ullah E, Ahmed M, et al. Efficacy of combination of ezetimibe and simvastatin versus atorvastatin in reducing low density lipoprotein-cholesterol in male patients of hypercholesterolemia, at Bahawalpur. Medical Forum Monthly 2008;19(5):3–9.

de Araujo DB, Bertolami MC, Ferreira WP, et al. Simvastatin 80 mg and coadministration of simvastatin 10 mg and ezetimibe 10 mg: Effects on LDL(−) and anti-LDL(−) antibodies. International Journal of Atherosclerosis 2007;2(4):272–8.

Ostad MA, Eggeling S, Tschentscher P, et al. Flow-mediated dilation in patients with coronary artery disease is enhanced by high dose atorvastatin compared to combined low dose atorvastatin and ezetimibe: Results of the CEZAR study. Atherosclerosis 2008 Dec 9;

Fleg JL, Mete M, Howard BV, et al. Effect of statins alone versus statins plus ezetimibe on carotid atherosclerosis in type 2 diabetes: the SANDS (Stop Atherosclerosis in Native Diabetics Study) trial. J Am Coll Cardiol 2008 Dec 16;52(25):2198–205.