# Appendix J Peer Reviewers

The UO-EPC gratefully acknowledges the following individuals who reviewed the initial draft of this evidence report, and provided constructive feedback. Acknowledgement does not reflect endorsement of this report.

- Dr. Rochelle Fu, Ph.D.
- Department of Public Health and Preventitive Medicine
- Oregon Health & Science University Portland, Oregon

- Dr. Ashfaq Shuaib, M.B.B.S., FRCPC
- Division of Neurology University of Alberta
- Edmonton, Alberta

- Dr. Theodore Ganiats, M.D.
- Department of Family and Preventive Medicine
- University of California—San Diego San Diego, CA