# Appendix A Search Strategies

## Main Search, MEDLINE (1966 to August Week 3 2008)

1. exp Hydroxymethylglutaryl-CoA Reductase Inhibitors/
2. Heptanoic Acids/
3. (Statin$ or reductase inhibitor$).tw.
4. (Simvastatin or Atorvastatin or Rosuvastatin or Pravastatin or Lovastatin or Fluvastatin or Mevastatin or Pitavastatin).mp.
5. (110862-48-1 or 287714-41-4 or 75330-75-5 or 79902-63-9 or 81093-37-0 or 93957-54-1).rn.
6. or/1–5
7. exp fatty acids, omega-3/
8. fatty acids, essential/
9. Dietary Fats, Unsaturated/
10. linolenic acids/
11. exp fish oils/
12. (n 3 fatty acid$ or omega 3).tw.
13. eicosapenta?noic.tw,hw,rw.
14. docosahexa?noic.tw,hw,rw.
15. alpha linolenic.tw,hw,rw.
16. (linolenate or cervonic or timnodonic).tw,hw,rw.
17. (mediterranean adj diet$).tw.
18. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
19. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
20. (fish adj2 oil$).tw.
21. (cod liver oil$ or marine oil$ or marine fat$).tw.
22. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
23. (fish consumption or fish intake or (fish adj2 diet$)).tw.
24. or/7–23
25. (anticholesteremic resin$ or (bile adj3 resin$) or BAR or BAS or Sequestrant$ or Bile acid$).tw.
26. (cholestyramine or colestyramin$ or quantalan or questran or colesevelam).tw.
27. Cholestyramine/
28. Colestipol/
29. (colestimide or colestilan or colestipol).tw.
30. or/25–29
31. ezetimibe.mp.
32. 163222-33-1.rn.
33. (cholester$ adj3 inhibit$).tw.
34. or/31–33
35. (fibrate$ or fibric acid$).tw.
36. Clofibric acid/
37. Clofibrate/
38. Bezafibrate/
39. Gemfibrozil/
40. Procetofen/
41. (gemfibrozil or fenofibrate or bezafibrate or clofibrate or clofibric acid or procetofen or ciprofibrate).tw.
42. (637-07-0 or 25812-30-0 or 41859-67-0 or 882-09-7 or 49562-28-9).rn.
43. or/35–42
44. niacin/
45. nicotinic acid/
46. niacin.tw.
47. or/44–46
48. (Zetia or Lopid or Tricor or Lofibra or Welchol or Colestid or Questran or Prevalite).mp.
49. Drug Therapy, Combination/
50. (combination adj3 therapy).tw.
51. add-on therapy.tw.
52. or/49–51
53. 6 and (or/24,30,34,43,47–48,52)
54. clinical trial.pt.
55. clinical trials/
56. (randomized or randomly or placebo).ab.
57. trial.ti.
58. randomized controlled trial.pt.
59. or/54–58
60. 53 and 59
61. or/24,30,34,43,47–48,52
62. exp Cardiovascular Diseases/
63. 61 and 62
64. or/6,63
65. limit 64 to systematic reviews
66. limit 64 to meta analysis
67. or/60,65–66
68. limit 67 to (english language and yr="1980 – 2007")
69. remove duplicates from 68

## Main Search, Embase (1980 to 2008 Week 36)

1. exp Hydroxymethylglutaryl Coenzyme a Reductase Inhibitor/
2. (Statin$ or reductase inhibitor$).tw.
3. (Simvastatin or Atorvastatin or Rosuvastatin or Pravastatin or Lovastatin or Fluvastatin or Mevastatin or Pitavastatin).mp.
4. (110862-48-1 or 287714-41-4 or 75330-75-5 or 79902-63-9 or 81093-37-0 or 93957-54-1).rn.
5. or/1–4
6. Omega 3 Fatty Acid/
7. exp Essential Fatty Acid/
8. exp Unsaturated Fatty Acid/
9. Fish oils/
10. (n 3 fatty acid$ or omega 3).tw.
11. eicosapenta?noic.tw,hw,rw.
12. docosahexa?noic.tw,hw,rw.
13. alpha linolenic.tw,hw,rw.
14. (linolenate or cervonic or timnodonic).tw,hw,rw.
15. (mediterranean adj diet$).tw.
16. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
17. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
18. (fish adj2 oil$).tw.
19. (cod liver oil$ or marine oil$ or marine fat$).tw.
20. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
21. (fish consumption or fish intake or (fish adj2 diet$)).tw.
22. or/6–21
23. Bile Acid Sequestrant/
24. (anticholesteremic resin$ or (bile adj3 resin$) or BAR or BAS or Sequestrant$ or Bile acid$).tw.
25. (cholestyramine or colestyramin$ or quantalan or questran or colesevelam).tw.
26. Cholestyramine/
27. Colestipol/
28. Colestyramine/
29. Colestilan/
30. (colestimide or colestilan or colestipol).tw.
31. or/23–30
32. Ezetimibe/
33. ezetimibe.mp.
34. 163222-33-1.rn.
35. or/32–34
36. Fibric Acid Derivative/
37. (fibrate$ or fibric acid$).tw.
38. Clofibric acid/
39. Clofibrate/
40. Bezafibrate/
41. Gemfibrozil/
42. Procetofen/
43. (gemfibrozil or fenofibrate or bezafibrate or clofibrate or clofibric acid or procetofen or ciprofibrate).tw.
44. (637-07-0 or 25812-30-0 or 41859-67-0 or 882-09-7 or 49562-28-9).rn.
45. or/36–44
46. nicotinic acid/
47. niacin.tw.
48. or/46–47
49. (Zetia or Lopid or Tricor or Lofibra or Welchol or Colestid or Questran or Prevalite).mp.
50. Drug Therapy, Combination/
51. (combination adj3 therapy).tw.
52. add-on therapy.tw.
53. or/50–52
54. 5 and (or/22,31,35,45,48–49,53)
55. limit 54 to "treatment (2 or more terms high specificity)"
56. clinical trials/
57. (randomized or randomly or placebo).ab.
58. trial.ti.
59. or/55–58
60. 54 and 59
61. or/22,31,35,45,48–49,53
62. exp Cardiovascular Disease/
63. 61 and 62
64. 5 or 63
65. limit 64 to "reviews (2 or more terms high specificity)"
66. or/60,65
67. limit 66 to (english language and yr="1980 – 2007")

## Main Search, CENTRAL (The Cochrane Library, Issue 3, 2008)

1. exp Hydroxymethylglutaryl Coenzyme a Reductase Inhibitor/
2. (Statin$ or reductase inhibitor$).tw.
3. (Simvastatin or Atorvastatin or Rosuvastatin or Pravastatin or Lovastatin or Fluvastatin or Mevastatin or Pitavastatin).mp.
4. (110862-48-1 or 287714-41-4 or 75330-75-5 or 79902-63-9 or 81093-37-0 or 93957-54-1).rn.
5. or/1–4
6. Omega 3 Fatty Acid/
7. exp Essential Fatty Acid/
8. exp Unsaturated Fatty Acid/
9. Fish oils/
10. (n 3 fatty acid$ or omega 3).tw.
11. eicosapenta?noic.tw,hw,rw.
12. docosahexa?noic.tw,hw,rw.
13. alpha linolenic.tw,hw,rw.
14. (linolenate or cervonic or timnodonic).tw,hw,rw.
15. (mediterranean adj diet$).tw.
16. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
17. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
18. (fish adj2 oil$).tw.
19. (cod liver oil$ or marine oil$ or marine fat$).tw.
20. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
21. (fish consumption or fish intake or (fish adj2 diet$)).tw.
22. or/6–21
23. Bile Acid Sequestrant/
24. (anticholesteremic resin$ or (bile adj3 resin$) or BAR or BAS or Sequestrant$ or Bile acid$).tw.
25. (cholestyramine or colestyramin$ or quantalan or questran or colesevelam).tw.
26. Cholestyramine/
27. Colestipol/
28. Colestyramine/
29. Colestilan/
30. (colestimide or colestilan or colestipol).tw.
31. or/23–30
32. Ezetimibe/
33. ezetimibe.mp.
34. 163222-33-1.rn.
35. or/32–34
36. Fibric Acid Derivative/
37. (fibrate$ or fibric acid$).tw.
38. Clofibric acid/
39. Clofibrate/
40. Bezafibrate/
41. Gemfibrozil/
42. Procetofen/
43. (gemfibrozil or fenofibrate or bezafibrate or clofibrate or clofibric acid or procetofen or ciprofibrate).tw.
44. (637-07-0 or 25812-30-0 or 41859-67-0 or 882-09-7 or 49562-28-9).rn.
45. or/36–44
46. nicotinic acid/
47. niacin.tw.
48. or/46–47
49. (Zetia or Lopid or Tricor or Lofibra or Welchol or Colestid or Questran or Prevalite).mp.
50. Drug Therapy, Combination/
51. (combination adj3 therapy).tw.
52. add-on therapy.tw.
53. or/50–52
54. 5 and (or/22,31,35,45,48–49,53)
55. exp Hydroxymethylglutaryl-CoA Reductase Inhibitors/
56. Heptanoic Acids/
57. (Statin$ or reductase inhibitor$).tw.
58. (Simvastatin or Atorvastatin or Rosuvastatin or Pravastatin or Lovastatin or Fluvastatin or Mevastatin or Pitavastatin).mp.
59. (110862-48-1 or 287714-41-4 or 75330-75-5 or 79902-63-9 or 81093-37-0 or 93957-54-1).rn.
60. or/55–59
61. exp fatty acids, omega-3/
62. fatty acids, essential/
63. Dietary Fats, Unsaturated/
64. linolenic acids/
65. exp fish oils/
66. (n 3 fatty acid$ or omega 3).tw.
67. eicosapenta?noic.tw,hw,rw.
68. docosahexa?noic.tw,hw,rw.
69. alpha linolenic.tw,hw,rw.
70. (linolenate or cervonic or timnodonic).tw,hw,rw.
71. (mediterranean adj diet$).tw.
72. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
73. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
74. (fish adj2 oil$).tw.
75. (cod liver oil$ or marine oil$ or marine fat$).tw.
76. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
77. (fish consumption or fish intake or (fish adj2 diet$)).tw.
78. or/61–77
79. (anticholesteremic resin$ or (bile adj3 resin$) or BAR or BAS or Sequestrant$ or Bile acid$).tw.
80. (cholestyramine or colestyramin$ or quantalan or questran or colesevelam).tw.
81. Cholestyramine/
82. Colestipol/
83. (colestimide or colestilan or colestipol).tw.
84. or/79–83
85. ezetimibe.mp.
86. 163222-33-1.rn.
87. (cholester$ adj3 inhibit$).tw.
88. or/85–87
89. (fibrate$ or fibric acid$).tw.
90. Clofibric acid/
91. Clofibrate/
92. Bezafibrate/
93. Gemfibrozil/
94. Procetofen/
95. (gemfibrozil or fenofibrate or bezafibrate or clofibrate or clofibric acid or procetofen or ciprofibrate).tw.
96. (637-07-0 or 25812-30-0 or 41859-67-0 or 882-09-7 or 49562-28-9).rn.
97. or/89–96
98. niacin/
99. nicotinic acid/
100. niacin.tw.
101. or/98–100
102. (Zetia or Lopid or Tricor or Lofibra or Welchol or Colestid or Questran or Prevalite).mp.
103. Drug Therapy, Combination/
104. (combination adj3 therapy).tw.
105. add-on therapy.tw.
106. or/103–105
107. 60 and (or/78,84,88,97,101–102,106)
108. or/54,107
109. remove duplicates from 108
110. limit 109 to yr="1980 – 2007"

## Harms Search, MEDLINE (1966 to August Week 3 2008)

1. exp Neoplasms/
2. Rhabdomyolysis/
3. Myocardial Infarction/
4. exp Liver Failure/
5. Stroke/
6. mo.fs.
7. or/1–6
8. (ae or po or to or mo or ci or de or et or co or sc).fs.
9. exp Survival Analysis/
10. exp Death/
11. Risk factors/
12. exp Drug Interactions/
13. Critical Illness/
14. exp Mortality/
15. Abnormalities, drug-induced/
16. exp Drug Hypersensitivity/
17. exp Drug Toxicity/
18. exp Product Surveillance, Postmarketing/
19. Cohort Studies/
20. harm$.mp.
21. ((adverse or serious or severe) adj2 (event$ or reaction$)).mp.
22. ((side or unwanted or adverse or undersire$) adj effect$).tw.
23. (ADR or ADRS or SAE).tw.
24. safety.mp.
25. (bleed$ or haemorrhag$ or hemorrhag$).tw.
26. (toxic$ or gastrotoxic$).tw.
27. (tolerability or tolerance or tolerate$).tw.
28. (relative risk or risks).mp.
29. risk.ti.
30. (cohort adj2 stud$).ti,ab.
31. (treatment emergent or complications).tw.
32. or/8–31
33. Databases/ or Databases, factual/ or National Practitioner Data Bank/
34. Prescriptions, Drug/sn
35. Hospitalization/sn
36. Managed Care Programs/sn
37. (administrative adj2 data$).tw.
38. (PHSHG or Public Health Strategic Healthcare Group or Palo Alto Medical Foundation or PAMF or MedPar or MCBS or Medicare Current Beneficiary Survey or Health Insurance Skeleton Eligibility Write-Off or HISKEW or UPIN or Unique Physician Identification Numbers or CAHPS or HOS or Health Outcomes Study or DSH or Providence BC or Partners Health Care or MEPS or Medical Expenditure Panel Survey or USP MEDMARX or Intensive Care Unit Safety Reporting System or ICU-SRS or i3Magnifi or Ingenix or American Heart Association or PCN or Primary Care Network or CORRONA or VA National Patient database or VA National Patient DB or VANPDB or VA Medicare Database or VAMD or Walgreen$ or Marketscan or Illinois Medicaid or Commercial Food Workers Union or CMS or VHA or Baltimore Veterans Healthcare or Thomson Medstat or Omnicare or HMO Research Network or HMORN or Healthinsight or Utah Population Database or NAMCS or National Ambulatory Medical Care Survey or Pharmetrics or NDTI or Mediplus or Tennessee Medicaid or TENNCARE or GPRD or General Practice Research Database or IMS Disease Analyzer).tw.
39. (California Medicaid or IMS HEALTH National Disease or (Consortium adj Rheumatology Researchers) or Illinois Department or British Columbia).tw.
40. ((French System adj2 Pharmacovigilance) or (ADR Centre adj2 Vietnam) or (WHO Collaborating Programme adj International Drug Monitoring) or (Medicines Evaluation adj Monitoring) or Medicines Evaluation or (Medicaid Pharmaceutical Analysis adj Surveillance)).tw.
41. (VSR or ADRAC or ADR Advisory Committee or CADRMP or Canadian ADR Monitoring Programme or Adverse Reactions Monitoring or BfArM or Voluntary Reporting System or National Reporting System or Farmacovigilanza or Farmacovigilancia or National Drug Monitoring System or National Adverse Reaction Monitoring Programme or Netherlands Pharmacovigilance Foundation or LAREB or National Toxicology Group or Centre for Adverse Reaction Monitoring or Norwegian Medicines Control Authority or Pharmacovigilance or Drug Monitoring Department or Swiss Drug Monitoring Centre or SANZ or Yellow Card or Spontaneous Reporting System or MedMARx or PEM or IMMP or J-PEM or Saskatchewan Administrative Healthcare Utilization Databases or MEMO or BCDSP or Boston Collaborative Drug Surveillance or COMPASS or Uppsala Monitoring).tw.
42. (Saskhealth or Quebec medical claims database or Regie de l'assurance-maladie du Quebec or RAMQ or Nova Scotia Pharmacare or (Health Insurance Commission adj Australia) or Intercontinental Marketing Services Health or medwatch or Linked Health Database or BCLHD).tw.
43. (VAERS or Vaccine Adverse Event Reporting System or adverse events reporting system or AERS or Fallon Health Plan or Harvard Pilgrim or Kaiser Permanente or ACOVE or (Assessing Care adj Vulnerable Elders)).tw.
44. (euromedstat group or euro med stat group).au.
45. or/33–44
46. exp Hydroxymethylglutaryl-CoA Reductase Inhibitors/
47. Heptanoic Acids/
48. (Statin$ or reductase inhibitor$).tw.
49. (Simvastatin or Atorvastatin or Rosuvastatin or Pravastatin or Lovastatin or Fluvastatin or Mevastatin or Pitavastatin).mp.
50. (110862-48-1 or 287714-41-4 or 75330-75-5 or 79902-63-9 or 81093-37-0 or 93957-54-1).rn.
51. or/46–50
52. exp fatty acids, omega-3/
53. fatty acids, essential/
54. Dietary Fats, Unsaturated/
55. linolenic acids/
56. exp fish oils/
57. (n 3 fatty acid$ or omega 3).tw.
58. eicosapenta?noic.tw,hw,rw.
59. docosahexa?noic.tw,hw,rw.
60. alpha linolenic.tw,hw,rw.
61. (linolenate or cervonic or timnodonic).tw,hw,rw.
62. (mediterranean adj diet$).tw.
63. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
64. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
65. (fish adj2 oil$).tw.
66. (cod liver oil$ or marine oil$ or marine fat$).tw.
67. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
68. (fish consumption or fish intake or (fish adj2 diet$)).tw.
69. or/52–68
70. (anticholesteremic resin$ or (bile adj3 resin$) or BAR or BAS or Sequestrant$ or Bile acid$).tw.
71. (cholestyramine or colestyramin$ or quantalan or questran or colesevelam).tw.
72. Cholestyramine/
73. Colestipol/
74. (colestimide or colestilan or colestipol).tw.
75. or/70–74
76. ezetimibe.mp.
77. 163222-33-1.rn.
78. (cholester$ adj3 inhibit$).tw.
79. or/76–78
80. (fibrate$ or fibric acid$).tw.
81. Clofibric acid/
82. Clofibrate/
83. Bezafibrate/
84. Gemfibrozil/
85. Procetofen/
86. (gemfibrozil or fenofibrate or bezafibrate or clofibrate or clofibric acid or procetofen or ciprofibrate).tw.
87. (637-07-0 or 25812-30-0 or 41859-67-0 or 882-09-7 or 49562-28-9).rn.
88. or/80–87
89. niacin/
90. nicotinic acid/
91. niacin.tw.
92. or/89–91
93. (Zetia or Lopid or Tricor or Lofibra or Welchol or Colestid or Questran or Prevalite).mp.
94. Drug Therapy, Combination/
95. (combination adj3 therapy).tw.
96. add-on therapy.tw.
97. or/94–96
98. 51 and (or/69,75,79,88,92–93,97)
99. or/7,32,45
100. 98 and 99
101. limit 100 to review
102. 100 not 101
103. limit 102 to (english and human and yr=1980–2007)

## Harms Search, Embase (1980 to 2008 Week 36)

1. exp neoplasms/
2. Rhabdomyolysis/
3. Myocardial Infarction/
4. exp Liver Failure/
5. Stroke/
6. mo.fs.
7. or/1–6
8. (ae or po or to or mo or ci or de or et or co or sc).fs.
9. exp Survival Analysis/
10. exp Death/
11. Risk factors/
12. exp Drug Interactions/
13. Critical Illness/
14. exp Mortality/
15. Abnormalities, drug-induced/
16. exp Drug Hypersensitivity/
17. exp Drug Toxicity/
18. exp Product Surveillance, Postmarketing/
19. Cohort Studies/
20. harm$.mp.
21. ((adverse or serious or severe) adj2 (event$ or reaction$)).mp.
22. ((side or unwanted or adverse or undersire$) adj effect$).tw.
23. (ADR or ADRS or SAE).tw.
24. safety.mp.
25. (bleed$ or haemorrhag$ or hemorrhag$).tw.
26. (toxic$ or gastrotoxic$).tw.
27. (tolerability or tolerance or tolerate$).tw.
28. (relative risk or risks).mp.
29. risk.ti.
30. (cohort adj2 stud$).ti,ab.
31. (treatment emergent or complications).tw.
32. or/8–31
33. Databases/ or Databases, factual/ or National Practitioner Data Bank/
34. Prescriptions, Drug/
35. Hospitalization/
36. Managed Care Programs/
37. (administrative adj2 data$).tw.
38. (PHSHG or Public Health Strategic Healthcare Group or Palo Alto Medical Foundation or PAMF or MedPar or MCBS or Medicare Current Beneficiary Survey or Health Insurance Skeleton Eligibility Write-Off or HISKEW or UPIN or Unique Physician Identification Numbers or CAHPS or HOS or Health Outcomes Study or DSH or Providence BC or Partners Health Care or MEPS or Medical Expenditure Panel Survey or USP MEDMARX or Intensive Care Unit Safety Reporting System or ICU-SRS or i3Magnifi or Ingenix or American Heart Association or PCN or Primary Care Network or CORRONA or VA National Patient database or VA National Patient DB or VANPDB or VA Medicare Database or VAMD or Walgreen$ or Marketscan or Illinois Medicaid or Commercial Food Workers Union or CMS or VHA or Baltimore Veterans Healthcare or Thomson Medstat or Omnicare or HMO Research Network or HMORN or Healthinsight or Utah Population Database or NAMCS or National Ambulatory Medical Care Survey or Pharmetrics or NDTI or Mediplus or Tennessee Medicaid or TENNCARE or GPRD or General Practice Research Database or IMS Disease Analyzer).tw.
39. (California Medicaid or IMS HEALTH National Disease or (Consortium adj Rheumatology Researchers) or Illinois Department or British Columbia).tw.
40. ((French System adj2 Pharmacovigilance) or (ADR Centre adj2 Vietnam) or (WHO Collaborating Programme adj International Drug Monitoring) or (Medicines Evaluation adj Monitoring) or Medicines Evaluation or (Medicaid Pharmaceutical Analysis adj Surveillance)).tw.
41. (VSR or ADRAC or ADR Advisory Committee or CADRMP or Canadian ADR Monitoring Programme or Adverse Reactions Monitoring or BfArM or Voluntary Reporting System or National Reporting System or Farmacovigilanza or Farmacovigilancia or National Drug Monitoring System or National Adverse Reaction Monitoring Programme or Netherlands Pharmacovigilance Foundation or LAREB or National Toxicology Group or Centre for Adverse Reaction Monitoring or Norwegian Medicines Control Authority or Pharmacovigilance or Drug Monitoring Department or Swiss Drug Monitoring Centre or SANZ or Yellow Card or Spontaneous Reporting System or MedMARx or PEM or IMMP or J-PEM or Saskatchewan Administrative Healthcare Utilization Databases or MEMO or BCDSP or Boston Collaborative Drug Surveillance or COMPASS or Uppsala Monitoring).tw.
42. (Saskhealth or Quebec medical claims database or Regie de l'assurance-maladie du Quebec or RAMQ or Nova Scotia Pharmacare or (Health Insurance Commission adj Australia) or Intercontinental Marketing Services Health or medwatch or Linked Health Database or BCLHD).tw.
43. (VAERS or Vaccine Adverse Event Reporting System or adverse events reporting system or AERS or Fallon Health Plan or Harvard Pilgrim or Kaiser Permanente or ACOVE or (Assessing Care adj Vulnerable Elders)).tw.
44. (euromedstat group or euro med stat group).au.
45. or/33–44
46. exp Hydroxymethylglutaryl-CoA Reductase Inhibitors/
47. Heptanoic Acids/
48. (Statin$ or reductase inhibitor$).tw.
49. (Simvastatin or Atorvastatin or Rosuvastatin or Pravastatin or Lovastatin or Fluvastatin or Mevastatin or Pitavastatin).mp.
50. (110862-48-1 or 287714-41-4 or 75330-75-5 or 79902-63-9 or 81093-37-0 or 93957-54-1).rn.
51. or/46–50
52. exp fatty acids, omega-3/
53. fatty acids, essential/
54. Dietary Fats, Unsaturated/
55. linolenic acids/
56. exp fish oils/
57. (n 3 fatty acid$ or omega 3).tw.
58. eicosapenta?noic.tw,hw.
59. docosahexa?noic.tw,hw.
60. alpha linolenic.tw,hw.
61. (linolenate or cervonic or timnodonic).tw,hw.
62. (mediterranean adj diet$).tw.
63. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
64. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
65. (fish adj2 oil$).tw.
66. (cod liver oil$ or marine oil$ or marine fat$).tw.
67. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
68. (fish consumption or fish intake or (fish adj2 diet$)).tw.
69. or/52–68
70. (anticholesteremic resin$ or (bile adj3 resin$) or BAR or BAS or Sequestrant$ or Bile acid$).tw.
71. (cholestyramine or colestyramin$ or quantalan or questran or colesevelam).tw.
72. Cholestyramine/
73. (colestimide or colestilan or colestipol).tw. [(colestimide or colestilan or colestipol).tw. as keyword]
74. Colestipol/ [Colestipol/ as keyword]
75. or/70–74
76. ezetimibe.mp.
77. 163222-33-1.rn.
78. (cholester$ adj3 inhibit$).tw.
79. or/76–78
80. (fibrate$ or fibric acid$).tw.
81. Clofibric acid/
82. Clofibrate/
83. Bezafibrate/
84. Gemfibrozil/
85. Procetofen/
86. (gemfibrozil or fenofibrate or bezafibrate or clofibrate or clofibric acid or procetofen or ciprofibrate).tw.
87. (637-07-0 or 25812-30-0 or 41859-67-0 or 882-09-7 or 49562-28-9).rn.
88. or/80–87
89. niacin/
90. nicotinic acid/
91. niacin.tw.
92. or/89–91
93. (Zetia or Lopid or Tricor or Lofibra or Welchol or Colestid or Questran or Prevalite).mp.
94. Drug Therapy, Combination/
95. (combination adj3 therapy).tw.
96. add-on therapy.tw.
97. or/94–96
98. 51 and (or/69,75,79,88,92–93,97)
99. or/7,32,45
100. 98 and 99
101. limit 100 to review
102. 100 not 101
103. limit 102 to (english and human and yr=1980–2007)

## Date and RCT Filters Removed, Medline (1950 to August Week 3 2008)

1. exp Hydroxymethylglutaryl-CoA Reductase Inhibitors/
2. Heptanoic Acids/
3. (Statin$ or reductase inhibitor$).tw.
4. (Simvastatin or Atorvastatin or Rosuvastatin or Pravastatin or Lovastatin or Fluvastatin or Mevastatin or Pitavastatin).mp.
5. (110862-48-1 or 287714-41-4 or 75330-75-5 or 79902-63-9 or 81093-37-0 or 93957-54-1).rn.
6. or/1–5
7. exp fatty acids, omega-3/
8. fatty acids, essential/
9. Dietary Fats, Unsaturated/
10. linolenic acids/
11. exp fish oils/
12. (n 3 fatty acid$ or omega 3).tw.
13. eicosapenta?noic.tw,hw,rw.
14. docosahexa?noic.tw,hw,rw.
15. alpha linolenic.tw,hw,rw.
16. (linolenate or cervonic or timnodonic).tw,hw,rw.
17. (mediterranean adj diet$).tw.
18. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
19. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
20. (fish adj2 oil$).tw.
21. (cod liver oil$ or marine oil$ or marine fat$).tw.
22. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
23. (fish consumption or fish intake or (fish adj2 diet$)).tw.
24. or/7–23
25. (anticholesteremic resin$ or (bile adj3 resin$) or BAR or BAS or Sequestrant$ or Bile acid$).tw.
26. (cholestyramine or colestyramin$ or quantalan or questran or colesevelam).tw.
27. Cholestyramine/
28. Colestipol/
29. (colestimide or colestilan or colestipol).tw.
30. or/25–29
31. ezetimibe.mp.
32. 163222-33-1.rn.
33. (cholester$ adj3 inhibit$).tw.
34. or/31–33
35. (fibrate$ or fibric acid$).tw.
36. Clofibric acid/
37. Clofibrate/
38. Bezafibrate/
39. Gemfibrozil/
40. Procetofen/
41. (gemfibrozil or fenofibrate or bezafibrate or clofibrate or clofibric acid or procetofen or ciprofibrate).tw.
42. (637-07-0 or 25812-30-0 or 41859-67-0 or 882-09-7 or 49562-28-9).rn.
43. or/35–42
44. niacin/
45. nicotinic acid/
46. niacin.tw.
47. or/44–46
48. (Zetia or Lopid or Tricor or Lofibra or Welchol or Colestid or Questran or Prevalite).mp.
49. Drug Therapy, Combination/
50. (combination adj3 therapy).tw.
51. add-on therapy.tw.
52. or/49–51
53. 6 and (or/24,30,34,43,47–48,52)
54. or/24,30,34,43,47–48,52
55. exp Cardiovascular Diseases/
56. 54 and 55
57. or/6,56
58. limit 57 to systematic reviews
59. limit 57 to meta analysis
60. or/53,58–59
61. limit 60 to english language