# Results

## Introduction

This chapter first describes the results of the literature searches and then provides the results for each Key Question, including key points, an overview of the studies identified for that question, and a detailed synthesis of the studies. The results of Key Question1, parts a through c, are presented together for each diagnostic method. The results for Key Question 1d are described following that section.

## Results of Literature Searches

Our searches identified 3,646 titles/abstracts, of which 3,391were excluded for the following reasons: not human (129), diagnostic methods beyond the scope of the review (129), not gout diagnosis or management (1,801), no original data or non-systematic reviews (374), conference proceedings or presentations or abstracts (11), case reports with sample size of fewer than 10 (415), population under age 18 (5), renal transplant or end-stage renal disease patients (12), titles with no abstracts (based on a survey of a random sample of 10 percent of these titles, for which full-text articles or reports were obtained, and all were rejected as letters, commentaries, or non-systematic reviews with no original data,) (252), gout management only (236) (see PRISMA diagram, Figure 2).

Figure 2 Literature flow diagram

KQ = Key Question; SR(s) = Systematic Review(s)

Figure 2 is the flow chart that summarizes the study retrieval and selection process for articles. The information displayed in the figure is described in the section entitled Results of Literature Searches.

We reviewed 255 full text articles, of which 234 were further excluded for the following reasons: participants not human (2), diagnostic methods beyond the scope of the review (44), not gout diagnosis or management (69), no original data (29), conference proceedings or presentations or abstracts not identified by title and abstract review (38), case reports with sample size fewer than 10 (17), gout management only (13), no reference standard reported or not all patients received the reference standard (7). We were unable to obtain articles for 15 studies.

Our search of Clinicaltrials.gov identified 152 entries, none of which were relevant to this review.

None of the manufacturers of imaging equipment or laboratory test kits used in the diagnosis of gout who were contacted for information responded to requests. A notice placed in the Federal Register requesting such information also generated no responses.

We include the results of 17 original studies16, 18, 28-42 and four systematic reviews43-46 in our evidence synthesis. Seventeen of the original studies answer Key Question 1, and 2 studies answer Key Question 2. Results for these studies can be found below by Key Question.

Appendix B contains the list of the studies excluded at full text review, and Appendix D contains our data abstraction tool and QUADAS-2 tools, which were used on the included studies, and the AMSTAR tool, which was used to assess the quality of the included systematic reviews.

The findings are organized as follows. For Key Question 1a through c, we present first the key points, followed by a brief overview of the studies and then detailed narrative descriptions of each study and prior systematic review that addresses that question or subquestion. The studies that address Key Question 1d and Key Question 2 are described separately, with the key points followed by the study details.

## Key Question 1 a. What is the accuracy of clinical signs and symptoms and other diagnostic tests (such as serum uric acid, ultrasound, CT scan, DECT, and plain x-ray), alone or in combination, compared with^b^ b Using monosodium urate crystal analysis of synovial fluid as the reference standard. synovial fluid analysis in the diagnosis of acute gouty arthritis, and how does the accuracy affect clinical decisionmaking, clinical outcomes and complications, and patient centered outcomes? b. How does the diagnostic accuracy of clinical signs and symptoms and other tests vary by affected joint site and number of joints? c. Does the accuracy of diagnostic tests for gout vary by duration of symptoms (i.e., time from the beginning of a flare)

### Key Points

- Few studies that assessed the accuracy of algorithms comprising clinical signs and symptoms for the diagnosis or classification of gout consistently applied the same reference standard to all participants with suspected gout and usually did not limit participation to individuals experiencing a first attack.
- Studies that assessed the use of clinical algorithms reported widely varying sensitivities and specificities; however, two recent diagnostic algorithms, one developed from clinical signs and symptoms used by primary care physicians, reported relatively good sensitivity and specificity but need further validation in larger, more varied populations. The strength of evidence for this conclusion is low.
- In small numbers of studies that enrolled only patients not previously diagnosed with gout, DECT had good sensitivity and specificity for predicting gout compared with synovial fluid analysis for MSU crystals or a validated diagnostic clinical algorithm. Three studies revealed sensitivities that ranged from 85% to 100% and specificities that ranged from 83% to 92%.
- Ultrasound was more varied in its ability to detect gout: Four studies of ultrasound showed sensitivities that ranged from 37% to 100% and specificities that ranged from 68% to 97%, depending on the signs assessed. The strength of evidence for this conclusion is low.
- No studies were identified that assessed the validity of serum uric acid, CT scan, or plain x-ray for diagnosing gout. The strength of evidence for these tests is insufficient.
- No studies were identified that directly assessed the effect of joint site or number of affected joints on diagnostic accuracy. The strength of evidence for this question is insufficient for all diagnostic methods.
- No studies were identified that directly assessed the effect of duration of symptoms on the accuracy of diagnostic tests. The strength of evidence for this question is insufficient for all diagnostic methods.

### Description of Included Studies

We identified 15 original studies that met our inclusion criteria for studies on the comparative effectiveness (validity) of methods for the diagnosis or classification of gout: 9 studies assessed the sensitivity and specificity of algorithms comprising combinations of clinical signs and symptoms,16, 31-34, 39-42 3 assessed the use of DECT,18, 28, 30 and 4 assessed the use of ultrasound (one study compared ultrasound and DECT).30, 35, 36, 38 We also identified four prior systematic reviews: one that addressed a clinical algorithm,46 two that assessed the use of imaging for diagnosis of gout43, 45 and one on sex differences in gout diagnosis.44

The nine studies that assessed the use of clinical diagnostic or classification algorithms each compared the predictions based on six clinical algorithms to assessment of synovial fluid MSU crystals in all or most enrolled patients or at least in those presumed to have gout (in the latter case, patients who were considered not to have gout had to have another condition confirmed by a validated diagnostic criterion). These studies, which dated from 1977, enrolled 82 to 983 adult patients, both male and female. All studies were conducted in academic rheumatology departments, although several of the studies purposefully enrolled patients who were recruited by primary care physicians. Table 1 describes the studies and Table 2 compares the components of each algorithm.

Table 1 Summary of included studies of algorithms comprising clinical signs and symptoms used to diagnose gout

Author, Year Country Practice Setting | Population n, Putative Diagnosis, Mean Age, % Female | Test Components/Reference Standard | Outcome Measures and Findings | Conclusions and Other Comments
Wallace 1977^42^ U.S. 38 academic or private rheumatology practices | 706 patients (178 gout; remainder pseudogout, RA, acute septic arthritis) Mean age: 61 % female: 13.6 (gout) (51-64% remainder ) Disease duration not reported | ARA criteria: Maximum inflammation 1 day >1 attack Monoarticular arthritis Redness 1^st^ MTP pain or swelling Unilateral first MTP Unilateral tarsal Suspected tophus Hyperuricemia Asymmetric swelling Subcortical cysts, no erosions Culture negative Reference: positive join MSU, proven tophi, or survey findings | Sensitivity, specificity of increasing numbers of criteria 50.6% of gout patients had joint aspiration (compared with 25% of RA patients, 82.7% of pseudogout patients, 23.7% RA patients, and 70.6% of SA patients); Of those gout patients who underwent MSU, 85% were positive. Presence of tophi had 99% specificity but not absolute. ≥5 +Clinical criteria: Sensitivity: 95.5% Specificity: 72.7-93.3% ≥6+criteria: Sensitivity: 87.6% Specificity: 89.1%-98.7% (pseudogout and SA, respectively) ≥7+criteria: Sensitivity: 74.1% Specificity: 97.3%-100% | A score of 6 or more among the 12 ARA criteria showed high sensitivity and specificity for predicting gout and discriminating from pseudogout, RA, and SA
Malik 2009^16^ US VA rheumatology clinic [Include] | 82 patients (37% MSU+) Mean age 64.5 6% female Disease duration not reported | ARA Criteria: See Wallace ‘77 NY Criteria: MSU crystals in joint fluid or tissue or tophus OR meets 2 of the following criteria: 2 attacks of painful limb joint swelling Abrupt onset and remission in 1–2 wk initially First MTP attack Presence of a tophus Response to colchicine-major reduction in inflammation within 48 h Rome Criteria: Meets 2 of the following criteria: Painful joint swelling, abrupt onset, Clearing in 1–2 wk initially Serum uric acid: 7 in males, 6 in Females Presence of tophi Presence of monosodium urate crystals (MSU) in synovial fluid or tissues Reference: SF MSU crystal analysis | Sensitivity and specificity, PPV 6/12 ARA: Sensitivity: 70.0% Specificity: 78.8% PPV:65.6% 2 of 4 NY Criteria: Sensitivity: 70.0% Specificity: 82.7% PPV:70.0% 2 of 3 Rome: Sensitivity: 66.7% Specificity: 88.5% PPV:76.9% (Table 3 of Malik reports the sensitivity, specificity, PPV and likelihood ratio for all ARA criteria and others) | Considering only the clinical elements in the 3 sets of criteria (i.e., not MSU crystal presence), no sets of clinical criteria were more than 70.0% sensitive or 88.5% specific. Having 2 of the 3 Rome criteria had the highest PPV of 76.9%. Authors conclude MSU analysis should remain gold standard.
Janssens 2010a31 Netherlands Primary care clinics | 328 patients with monoarthritis (but otherwise blinded PCP diagnosis) Mean age: 58.0 (13.) years, % female: 20.4% Recruited consecutively from primary care clinics with Disease duration not reported | Family physician diagnosis, patient-level factors (e.g., age, sex, CVD, onset within one day or hour, family history, medication use; Table 1 of Janssens includes all variables considered) Reference: SF MSU crystal analysis | PPV, NPV, AUC Family physician diagnosis: PPV: 0.64 NPV: 0.87 3 multivariate models were constructed. The most appropriate model contained the following predefined variables: Male sex Previous patient-reported arthritis attack Onset within 1 day Joint redness MTP 1 joint involvement Hypertension or1or more CVD, and sUA > 5.88mg/dL* AUC 0.85 (95% CI 0.81-0.90). | Performance did not change after transforming the regression coefficients to easy-to-use scores and was almost equal to that of the statistically optimal model (AUC 0.87; 95% CI,0.83-0.91)
Janssens 2010b32 Netherlands | 381 monoarthritis patients recruited from primary care clinics (328 with PCP diagnosis of gout) (same population as Janssens 2010a) | ARA/ACR criteria Reference Standard: SF MSU crystal analysis | [underlined: ARA/ACR criteria (≥4 +)] Sensitivity: 1.00, Specificity: 0.24 PPV:0.70 NPV: 0.97 Overall fraction correct: 72% [underlined: ARA/ACR criteria (≥6 +)] Sensitivity: 0.80 Specificity: 0.64 PPV:0.80 NPV: 0.65 Overall fraction correct: 74% [underlined: ARA/ACR criteria (≥ 9 +)] Sensitivity: 0.07 (15/209) Specificity: 0.99 (118/119) PPV: 0.94 (15/16) NPV: 0.38 (118/312) Overall fraction correct: 41% (133/328) | Increasing stringency of ARA criteria beyond the cutoff point of 6 or more criteria did not improve usability of the criteria greatly: Patients referred from primary care with suspected gout (monoarthritis) assessed with MSU showed that the ARA/ACR criteria not particularly useful in diagnosis.
Vazquez-Mellado 2012^41^ Mexico Academic rheumatology departments | 167 consecutive patients with diagnoses of RA, OA, SpA, or gout (75) Mean age: 45 % female: 24% (gout); 90% (OA) Disease duration not reported | Clinical gout diagnostic [CGD] criteria= ≥4/8 of the following: Current/past history of >1 attack of acute arthritis Mono- or oligoarthritis Rapid progression of pain/swelling (<24 hours) Podagra Erythema Unilateral tarsitis Tophi Hyperuricemia Reference standard: MSU crystal analysis performed in all gout patients | Sensitivity, specificity, AUC, PPV, positive likelihood ratio of CGD criteria and effects of patient characteristics (obesity, HTN, CVD, dyslipidemia, hyperglycemia, metabolic syndrome, chronic renal failure) [underlined: ≥3 CGD items]: Sensitivity: 99.1 Specificity: 79.8 +LR: 4.90 -LR: 0.01 PPV: 85.6 NPV: 48.7 AUC: 0.90 [underlined: ≥4 CGD items:] Sensitivity: 97.3 (95% CI 90.8, 99.3) Specificity: 95.6 (89.2, 98.3) +LR: 22.1 -LR: 0.03 PPV: 94.8 NPV: 97.8 AUC: 0.96 | Authors state that study is limited by setting (rheumatology clinic vs. primary care setting) and the patient population likely to be seen (chronic vs. acute) but high concordance with other criteria, e.g., ACR suggests these criteria may be useful in primary care settings. Radiographic data not included because not specific. The mean CGD criteria in women: 5.22 (SD1.35) The mean CGD criteria in early-onset gout: 7.0(1.22) The kappa value comparing the CGD and the Janssens criteria was 0.85.
Kienhorst 2013^33^ Netherlands Academic rheumatology department | 390 patients with suspected gout referred to rheumatology clinic by PCPs; patients with crystal proven gout excluded (duration not reported) | Janssens diagnostic criteria31: Male sex (2*) Previous patient-reported arthritis attack (2)Onset within 1 day (0.5) Joint redness (1) MTP 1 involvement (2.5) HTN or ≥1CVD (1.5) sUA >0.35 mmol/L (5.88 mg/dL) (3.5) Reference standard: MSU crystal analysis performed in all patients *Points assigned to criterion | Prevalence of gout by cut-off scores (out of a possible 12): ≤4: PPV 5%; NPV 95% (4 of 69) >4 to <8: 46% (76 of 163) ≥8: PPV 87% (138 of 157) AUC: 0.86 (95% CI 0.82, 0.89) | Diagnostic criteria developed for primary care settings validated in secondary care population (i.e., patients referred by PCP to rheumatology for confirmation of suspected diagnosis). During followup, 28 patients who had been MSU- at baseline became MSU+.
Kienhorst 2014^34^ Netherlands Academic rheumatology department | 159 primary care patients recruited by PCPs and referred to academic rheumatology department for suspected gout based on MTP1 monoarthritis (of the initially recruited 381PCP patients with suspected gout) Mean age 58.3 % female: 15% confirmed gout, 47% non-gout | PCP diagnosis, primarily based on arthritis of MTP 1 joint, at baseline and, in MSU-, at followup of at least 1 year Reference standard: MSU crystal analysis performed in all patients | Sensitivity, specificity, PPV, NPV of PCP diagnosis at baseline and after followup of >1 year Additional differences in clinical signs and symptoms between gout and non-gout patients At baseline, 74.2% of patients were MSU+; During followup, 5 additional patients tested MSU+. 19 (11.9%) died during follow-up. PCP diagnosis: Sensitivity: 0.99 Specificity: 0.08 PPV: 0.79 NPV: 0.75 Positive likelihood ratio: 1.1 Negative likelihood ratio: 0.1 | Clinical signs and symptoms significantly increased in MSU+ patients by univariate analysis: male sex, previous arthritis, patient–reported gout, use of diuretics, use of CVD or antiHTN drugs, hypertension and/or CVD, beer consumption, BMI> 25, sUA>349umol/L, serum creatinine>105.2umol/L, GFR<60ml/min, CRP>1mg/dL (all p<0.05) Gout is a prominent cause but not the only cause of MTP-1 monoarthritis, which was incorrectly diagnosed as gout in 25% of patients. These additional signs and symptoms increase precision of diagnosis.
Richette 2014^39^ France Academic rheumatology departments | 246 patients (102 with MSU-confirmed gout and 142 MSU-minus controls) from 14 rheumatology departments who agreed to complete a questionnaire Mean age 60 % female: 15.7% confirmed gout, 58.5% without gout | 62-item phone questionnaire designed to be administered by non-medical personnel to elicit self-reported clinical signs and symptoms of gout (sociodemographic variables, comorbidities, and characteristics of the most prominent episode of gout) Reference standard: MSU crystal analysis | OR for item responses predicting cases of gout, as determined using multi-adjusted models. Sensitivity, specificity, Positive LR, negative LR, AUC for the logistic regression models and for self-reported gout. Model 1 (8 items): Sensitivity: 88.0% (79.6, 93.4) Specificity: 93% (87, 96.4) PLR: 12.5 (6.8, 22.8) NLR: 0.13 (0.08, 0.22) Correctly classified 90% (86.4, 94.1) AUC: 0.97 (0.95, 0.99) Model 2 (5 items): Sensitivity: 87.5% (79.6, 93.4) Specificity: 89.8% (82.9, 94.3) PLR: 8.6 (5.1, 14.5) NLR: 0.14 (0.08, 0.24) Correctly classified 88.8% (83.8, 94.192.5) AUC: 0.95 (0.92, 0.98) Classification and regression tree (CART): Sensitivity: 81.3% (72.2, 88.1) Specificity: 93.7% (88.0, 96.9) PLR: 12.8(6.8, 24.3) NLR: 0.20 (0.13, 0.30) Correctly classified 88.5% (83.7, 92.1) AUC:0.87(0.83, 0.91) | The 11-item questionnaire correctly classified gout patients more accurately than self-report. This questionnaire will be used to estimate the prevalence of gout in France.
Taylor 2014^40^ 25 centers in 16 countries Academic Rheumatology Departments (patients referred from primary care) | 983 patients (509 MSU+ for gout, 474 non-cases) | Assessment of Rome, New York, ARA, CGD, and Diagnostic Rule (Netherlands) criteria Reference standard: MSU crystal analysis for all patients | Sensitivities and specificities measured without MSU and with MSU (for algorithms that include it; not reported here) (sensitivity/specificity ≤2 yrs)(>2 yrs) Rome: (60/86) ((84/64) NY: (58/88) (88/70) ARA: 71/84) (92/53) Diag Rule: (88/75) (96/47) CGD: (87/66) (99/34) | Sensitivity of Dx Rule and CGD were higher than other algorithms and increased with disease duration.

ACR = American College of Rheumatology; ARA = American Rheumatism Association; AUC = area under the curve; BMI = body mass index; CGD = Clinical Gout Diagnosis; CI = confidence interval; CRP = c-reactive protein; CVD = cardiovascular disease; GFR = glomerular filtration rate; HTN = hypertension; LR = likelihood ratio; MSU = monosodium urate; MTP = metatarsophalangeal; OA = osteoarthritis; NPV = negative predictive value; NY = New York; PCP = primary care physician; SA = septic arthritis; SD = standard deviation; VA = Veterans Administration

Table 2 Comparison of components among clinical algorithms for diagnosis of gout

Components | Rome (1963)^a,16^ | NY (1966)^b,16^ | Wallace 1977 (ARA/ACR)42 | EULAR 2006^22^ | Janssens Diagnostic Rule 2010^31^ | Clinical Gout Diagnosis (CGD) 2010^41^ | 3e Initiative 2014^d,47^ | Richette Survey^e,39^
Clinical characteristics
>1 attack of acute arthritis | | ✓ | ✓ | | ✓ | ✓ | | ✓
Maximum inflammation developed within 1 day | ✓ painful joint swelling, abrupt onset, clearing 1-2 wk | ✓ | ✓ | ✓ | ✓ | ✓
Monoarthritis/oligoarthritis attack | | | ✓ | | | ✓
Redness observed over joints | | | ✓ | ✓ | ✓ | ✓
1^st^ MTP joint painful or swollen | | | ✓ | ✓ | ✓ | ✓ podagra | ✓ podagra
Unilateral 1^st^ MTP joint attack | | ✓ | ✓
Unilateral tarsal joint attack | | | ✓ | | | ✓
Abrupt onset and remission in 1-2 weeks initially | | ✓
Response to colchicine – major reduction in inflammation within 48h | | ✓ | | | | | ✓
Pain intensity≥9/10 | | | | | | | | ✓
Involvement of toes, foot, or ankles | | | | | | | | ✓
Treatment with corticosteroids | | | | | | | | ✓
Treatment with NSAIDS | | | | | | | | ✓
Resolution of pain<15 days after onset | | ✓ | ✓ | | | | | ✓
Tophi (proven or suspected) | ✓ | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓
Radiograph
Asymmetric swelling within a joint on radiograph | | | ✓ | ✓
Subcortical cysts without erosions on radiograph | | | ✓ | ✓
Joint fluid
Joint fluid culture negative | | | ✓
MSU crystals in synovial fluid or tissues^f^ | ✓ | | | | | | ✓
Comorbid or risk factors
Hyperuricemia | ✓ | | ✓ | ✓ | ✓ | ✓ | | ✓
Male sex | | | | | ✓ | | | ✓
Hypertension or ≥1 CVD | | | | | ✓ | | | ✓
Hypertriglyceridemia | | | | | | | | ✓

3e = Evidence , Expertise, Exchange; ACR = American College of Rheumatology; ARA = Amereican Rheumatology Association; CGD = clinical gout diagnosis; CVD = cardiovascular disease; EULAR = European League Against Rheumatism; MTP = metatarsophalangeal

Note: Podagra is gout that involves the big toe.

a Meets 2 of the following criteria.

b MSU crystals in joint fluid or tophus or tissue OR meets 2 of the following criteria.

c ≥4/8 of the following criteria.

d Guideline 1 states that MSU is required for a definitive diagnosis but in its absence, clinical criteria such as the following can be used or characteristic imaging findings may substitute.

e Designed to be administered telephonically by non-physicians to assess prevalence of gout via patient self-report; treatment questions refer to most prominent episode.

f Several algorithms specified presence of MSU crystals as definitive in lieu of other signs.

The three studies that assessed the use of DECT compared the predictions based on these imaging studies to assessment of synovial fluid MSU crystals or to a clinical diagnostic algorithm or some combination of the two reference standards. These studies dated from 2011 to 2014 and enrolled 31 to 94 patients with suspected gout. All studies were conducted in academic rheumatology departments.

The four studies that assessed the use of ultrasound compared the predictions based on these imaging studies to assessment of synovial fluid MSU crystals or to a clinical diagnostic algorithm or some combination of the two reference standards. These studies dated from 2008 to 2014 and enrolled 54 to 105 patients with monoarthritis or suspected gout.

### Detailed Synthesis

This section describes the included studies and the findings for each diagnostic method.

#### Studies Assessing Algorithms Comprising Clinical Signs and Symptoms To Diagnose Gout

##### Comparative Accuracy

Nine studies assessed the validity of diagnostic and classification algorithms comprising clinical signs and symptoms of gout against synovial fluid MSU analysis (Table 1). Table 2 compares the criteria assessed in the studies as well as additional guideline-based criteria. The QUADAS scores for risk of bias for each of the included studies are shown in Table 5 at the end of this chapter.

Table 5 Risk of bias assessment by QUADAS-2

Author, Year | Domain 1: Patient Selection | | | | Domain 2: Index Test(s) | | | Domain 3: Reference Standard | | | Domain 4: Flow and Timing
Author, Year | Consecutive/ random sample | Case-control design avoided? | Appropriate exclusions avoided? | Overall risk of bias | Index test results read without knowing reference standard? | Prespecified threshold? | Overall risk of bias | Reference standard correctly classifies target condition? | Reference standard read without knowing the index test? | Overall risk of bias | Appropriate interval between index test(s) and reference standard? | All patients received reference standard? | Same reference standard? | All patients included in the analysis? | Overall risk of bias
Bongartz et al., 2014^28^ | Yes | Yes | Unclear | Low | Yes | Yes | Low | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Glazebrook et al., 2011^18^ | Yes | Yes | Yes | Low | Yes | N/A | Low | Yes | Unclear | Unclear | No | Yes | Yes | No | Unclear
Huppertz et al., 2014^30^ | Yes | No | Unclear | High | Yes | N/A | Low | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Janssens, et al., 2010^32^ | Yes | Yes | Unclear | Low | Unclear | Yes | Unclear | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Low
Janssens et al., 2010^31^ | Yes | Yes | Yes | Low | Yes | Yes | Low | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Kienhorst et al., 2013^33^ | Yes | Yes | Yes | Low | Yes | Yes | Low | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Kienhorst et al., 2014^34^ | Yes | Yes | No | Low | Yes | N/A | Low | Yes | No | Unclear | Yes | Yes | Yes | Yes | Low
Lai et al., 2011^35^ | Yes | Yes | Unclear | Low | Yes | N/A | Low | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Low
Lamers-Karnebeek et al., 2014^36^ | Yes | Yes | No | Low | Yes | N/A | Low | Yes | Yes | Low | Yes | Yes | Yes | Yes | Low
Malik et al., 2009^16^ | Yes | Yes | Yes | Low | Yes | Yes | Low | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Low
Park et al., 2014^37^ | Yes | Yes | No | Low | N/A | N/A | N/A | Yes | N/A | Low | N/A | Yes | Yes | No | Unclear
Rettenbacher et al., 2008^38^ | Yes | Yes | Yes | Low | Yes | N/A | Low | Yes | Unclear | Unclear | Unclear | Yes | No | No | High
Richette et al., 2014^39^ | Unclear | No | Unclear | High | Yes | No | Unclear | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Unclear
Taylor et al., 2014^40^ | Yes | Yes | Yes | Low | Yes | Yes | Low | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Low
Vazquez-Mellado et al., 2012^41^ | Yes | No | Unclear | High | No | Yes | High | Yes | Yes | Low | Unclear | Yes | Yes | Yes | Low
Wallace et al., 1977^42^ | Unclear | No | Unclear | High | Unclear | Yes | High | Yes | Yes | Low | No | No | Yes | Unclear | High

N/A = not available

###### ARA/ACR Criteria

In 1977, the American Rheumatism Association (ARA, forerunner of the American College of Rheumatology [ACR]) Subcommittee on Classification Criteria for Gout, compiled a survey questionnaire comprising 53 proposed criteria for classifying acute gout, for epidemiology and for research, although the criteria are used for diagnosis and clinical decisionmaking.42 Thirty eight rheumatologists from 38 academic and private rheumatology clinics throughout the U.S. were invited to contribute data on up to 5 patients in each of five diagnostic categories: gout, rheumatoid arthritis of less than 2 years' duration, rheumatoid arthritis of more than 2 years duration, pseudogout, and septic arthritis. The draft diagnostic criteria were tested on 706 of the patients (average age: 61): 178 patients provisionally diagnosed with gout (average duration 10 years), 299 with rheumatoid arthritis, and the remainder with acute septic arthritis or pseudogout. The proportion of females was 13.6 percent for gout patients and ranged from 51 percent to 64 percent for the other disorders. Among the 178 patients presumed to have gout, 90 underwent joint aspiration (compared with 25 percent of the rheumatoid arthritis patients, over 80 percent of the pseudogout patients, and 70 percent of the septic arthritis patients); of those patients with clinical gout diagnoses tested for MSU, 85 percent had positive findings (no MSU-positive findings were seen among patients with any of the other diagnoses, indicating absolute specificity for MSU crystals). The 53 criteria included in the survey were narrowed to the 12 that best discriminated the study groups and showed the greatest balance of sensitivity (the proportion of MSU-positive patients who fulfilled the proposed criterion) and specificity (the proportion of control patients who did not fulfill the proposed criterion) (Table 1). The sensitivity of three different cutpoints—5 or more, 6 or more, and 7 or more positive criteria—were 95.5%, 87.6%, and 74.1%, respectively. The specificities for these cutpoints were 72.7%-93.3%, 89.1%-98.7%, and 97.3%-100%, respectively; in each case, the criteria showed the poorest discrimination between gout and pseudogout. The authors noted that in spite of the perfect specificity of MSU for diagnosing gout, few suspected gout patients underwent the test and the sensitivity was only moderate.

In 2009, researchers compared the ARA criteria42 with two briefer algorithms (see the Rome Criteria and the NY Criteria, below). They enrolled 82 patients (mean age 64.5, 6 percent female) at a Veterans Administration rheumatology clinic. The criterion for enrollment was having had synovial fluid aspirated and analyzed for MSU crystals (by two highly experienced rheumatologists) at some prior time; participants were surveyed but did not receive new physical exams for the study. Of the participants, 75.6 percent had undergone aspiration of a knee joint; the remainder had had the MTP, wrist, elbow, ankle, or proximal interphalangeal joint aspirated. Thirty patients of 82 were MSU crystal-positive. This study reported lower sensitivity (70%) and specificity (79%) for 6 of 12 of the ARA criteria than did Wallace and colleagues.

From 2004 to 2007, family physicians in the Netherlands consecutively recruited 381 patients with monoarthritis; the patients were sent, along with their blinded diagnosis, to an academic rheumatology clinic for MSU crystal analysis, clinical exam, and followup of at least 1 year. Of the 381, 328 patients (mean age 58.0; 20.4 percent female) had a diagnosis of gout by their primary care physician (PCP). The academic rheumatology researchers, led by Janssens, analyzed the patients' MSU to validate the PCP diagnoses and examined the patients to validate the ARA/ACR criteria against the presence of MSU crystals in synovial fluid. Increasing the cutoff points from 4 or more positive criteria (out of 11) to a maximum of 9 or more decreased the sensitivity from 100% to 7% and increased the specificity from 24% to 99%. The cutoff point of 6 or more criteria showed a sensitivity of 80% and a specificity of 64% (and a PPV of 0.80 and NPV of 0.65), leading the authors to conclude in a 2010 report that the ACR criteria had limited validity for classifying gout patients in primary care,32 most of whom presented with monoarthritis, usually in the MTP joint.

###### The Rome Criteria and New York Criteria

The New York Criteria and the Rome Criteria were the forerunners of the ARA Preliminary Criteria (the Rome criteria were first published in 1963 and the New York criteria were published in 1966) (Table 2).16 The New York criteria required crystals in synovial fluid, tissue, or tophus OR meeting two of five clinical criteria. The Rome criteria required meeting two of four criteria, one of which was MSU crystals in synovial fluid or tissue. As described above, the criterion for enrollment in the validation study was having had synovial fluid aspirated and analyzed for MSU crystals (by two highly experienced rheumatologists) at some prior time; participants were surveyed but did not receive new physical exams for the study. Of the participants, 75.6 percent had undergone aspiration of a knee joint; the remainder had had the MTP, wrist, elbow, ankle, or proximal interphalangeal joint aspirated. Thirty patients of 82 were MSU crystal-positive. Considering only the clinical signs and symptoms in the three sets of criteria (i.e., excluding MSU crystal findings), none of the clinical criteria sets had a sensitivity of more than 70.0% or a specificity of more than 88.5%. Having two of the three (non-MSU) Rome criteria had the highest specificity (88.55) but the sensitivity was 66.7%. Assessing the positive likelihood ratio (LR+) of individual criteria, they found that proven or suspected tophus and response to colchicine within 48 hours had the highest LR+ (15.56 [95%CI 2.11, 114.71] and 4.33[95%CI 1.16, 16.16], respectively) and positive predictive value (PPV) (91% and 86%, respectively) of any of the criteria in the three criteria sets. Although the study suggested basing future criterion sets on the Rome criteria because of its high specificity, patients were not necessarily having an acute attack and did not undergo physical exams, and MSU assessment had been conducted any time in the past.

###### The Diagnostic Rule (Netherlands Criteria)

Using the clinical signs and symptoms, along with the lab values (serum urate) and MSU assessments for the 381 consecutively enrolled primary care patients described above,32 Janssens and colleagues aimed to test the validity of PCP diagnosis of gout and to develop a diagnostic rule for use in primary care settings. Employing the criteria used by PCPs, they developed a set of multivariate predictive models (six clinical signs and symptoms, with and without the addition of serum urate testing). Again, of the 381 patients, 328 had a PCP diagnosis of gout; 64 percent were MSU crystal-positive (the PCPs' diagnosis had a PPV of 0.64 and a negative predictive value [NPV] of 0.87). All had monoarticular gout. The model with the highest area under the curve (AUC) (0.85, 95% CI 0.81, 0.90) contains the following elements: male sex, previous patient-reported arthritis attack, onset within 1 day, joint redness, first metatarsophalangeal joint (MTP1) involvement, hypertension or one or more cardiovascular disease, and serum urate level exceeding 5.88mg/dL (Figure 2). Omitting serum urate testing decreased the AUC only slightly (to 0.82).

In 2013, Janssens' group conducted additional analysis of their 2010 dataset to assess the sensitivity and specificity of monoarthritis of the MTP1 joint as a diagnostic criterion for gout, as this clinical sign was often the sole criterion used by Dutch PCPs to diagnose and initiate treatment of gout.34 The population comprised 159 of the initially recruited 381 patients, who had monoarthritis of MTP1. All patients underwent MSU-crystal assessment: At baseline, 118 (74.2 percent) of the patients had MSU crystals. The patients who did not have MSU crystals underwent a series of additional tests. Ten were diagnosed with a different rheumatic disease, and 31 received the diagnosis of unspecified monoarthritis. All of these patients were followed for at least 1 year; during this followup period, 5 additional patients tested positive for MSU crystals and were then classified as having gout, 12 fulfilled the criteria for a different rheumatic disease (3 osteoarthritis, 2 rheumatoid arthritis, 1 psoriatic arthritis, 1 calcium pyrophosphate deposition disease, 4 other types of arthritis, 1 bunion) and 24 were given the diagnosis of an unspecified monoarthritis (during a subsequent 5-year followup, 19 died). The PCP diagnosis based on MTP1 monoarthritis had a sensitivity of 99% and a specificity of 8%, (PPV was 0.79, and NPV was 0.75 in this population). The authors concluded that this clinical sign was a promising predictor of gout but not entirely reliable (as 20 percent of patients were incorrectly diagnosed with gout and 25 percent were missed).

Janssens' group also validated their criteria set on a group of 390 patients seen in a rheumatology clinic for the first time between 2011 and 2013 with signs and symptoms suggestive of gout.33 These patients were referred by PCPs for suspicion of gout based on clinical exam. Of the 390 patients, 56 percent had a positive finding of MSU crystals (diagnoses of MSU-negative patients were not further described). At cutoff scores of 4 or fewer positive criteria, 4 to 7 positive criteria, and 8 or more positive criteria, the likelihood of a positive MSU finding was 6 percent, 46 percent, and 88 percent, respectively. The AUC was 0.85 and the Hosmer-Lemeshow goodness of fit was non-significant (0.64), suggesting that the criteria set developed for use in a primary care population works equally well in the rheumatology setting.

###### The Clinical Gout Diagnosis Criteria

In 2010, Vazquez-Mellado and colleagues developed an 8-item set of criteria, the Clinical Gout Diagnosis (CGD) criteria, which were a subset of the ACR criteria, to diagnose chronic gout in the primary care setting without reliance on joint fluid analysis of MSU. They sought to validate the criteria on a population of patients suspected of having gout or another inflammatory arthritis.41 They recruited 167 consecutive patients (mean age 45; 24 percent of gout patients were female, compared with 90 percent of osteoarthritis patients) seen in a Mexico City academic rheumatology clinic; 75 had MSU crystal-positive+ gout (many were in the intercritical period, i.e., between flares, suggesting MSU analysis might have taken place at some time prior to the study), and the remainder met diagnostic criteria for rheumatoid arthritis (30), osteoarthritis (31), or spondyloarthritis (31). At a cutoff point of 4 or more positive items out of 8, the sensitivity was 97.3% and the specificity was 95.6% (3 percent of rheumatoid arthritis patients, 7 percent of septic arthritis patients, and 3 percent of osteoarthritis patients fulfilled 4 or more of the 8 criteria); the LRP was 22.1 and the LRN was 0.03. The mean score for all MSU crystal-positive patients was 6.27 (SD1.39). In comparison, the mean score for female gout patients was 5.22(SD 1.35) and the mean score for patients with earlier onset of gout symptoms was 7.0(SD 1.22). All patients with early-onset gout and 94.4 percent of female gout patients fulfilled 4 or more of the CGD criteria.

###### Comparison of Diagnostic/Classification Criteria

As part of a joint ACR/EULAR effort to update gout classification criteria called The Study for Updated Gout classification cRiteria (SUGAR), gout researchers compared the performance of the major gout diagnostic/classification clinical algorithms in early and established gout (the Rome, New York, ARA, Netherlands Diagnostic Rule, and Mexican CGD).40 The researchers recruited 983 consecutive patients attending rheumatology clinics in 16 countries with a joint swelling or subcutaneous nodule within the previous 2 weeks that was suggestive of gout. Clinical assessments and provisional diagnoses were made on all patients prior to MSU analysis. MSU crystals were identified in 509 (52 percent) patients, 144 of whom self-described early disease (less than 2 years); 228 were determined to be in the early stages of another inflammatory arthritis). Across all criteria sets, sensitivity was higher in longer-term disease, and specificity was higher in those with shorter duration disease. Because four of the criteria allowed for a diagnosis based on MSU crystals, researchers assessed the sensitivity and specificity with and without MSU. Among recent onset patients, the Diagnostic Rule and the CGD had the highest sensitivity but lower specificity (88% and 87%/75% and 66%, respectively); the New York had the lowest sensitivity but highest specificity (58%/88%). Among patients with longer duration disease, the CGD had the highest sensitivity and lowest specificity (99%/34%) (the highest specificity in this group was shown by the New York criteria (88% sensitivity/70% specificity). All of the criteria sets had somewhat poor specificity in longer-duration disease and the Diagnostic Rule and CGD had poorer specificity in early disease. The authors concluded that the Rome clinical criteria had the best overall performance for both early and established disease (60% and 84% sensitivity/86% and 64% specificity) but that without performing MSU analysis, none of the criteria have adequate specificity.

###### French Telephone Survey Questionnaire

In 2014, a group of French rheumatologists published the results of their attempt to develop and validate a telephone survey/questionnaire to be used by non-medical personnel to elicit self-reports of gout for epidemiological studies (most immediately, to establish the prevalence of gout in France).39 They recruited a cohort of 246 patients with inflammatory arthritis who had undergone synovial fluid aspiration and analysis (102 had MSU crystal-confirmed gout and 142 had no MSU crystals) from 14 rheumatology departments throughout France (patients were age 18 or over, mean age 60, 15.7 percent females among gout patients and 58.5 percent without gout). The questionnaire contained 62 items; based on the odds ratios of individual items for predicting gout, the researchers developed two logistic regression models, one with 9 of the most predictive items and one with 5 items, and a classification and regression tree (CART) model that contained the 11 items included in the two regression models (Table 2). As shown in Table 1, the three models had similar performance, correctly classifying 90.0 percent, 88.8 percent, and 88.5 percent of patients.

##### Effect of Test Accuracy on Clinical Decisionmaking, Clinical Outcomes and Complications, and Patient-Centered Outcomes

No studies were identified that tested the effects of the accuracy of gout diagnoses based on clinical signs and symptoms on clinical decisionmaking (treatment decisions or decisions to conduct further testing), clinical outcomes, or patient centered outcomes.

##### Effect of Affected Joint Site(s) and Number of Joints on the Diagnostic Accuracy of Clinical Signs and Symptoms

No studies were identified that directly tested the effects of the joint site affected or the number of joints affected on the accuracy of diagnostic tests based on clinical signs and symptoms. One study described above assessed the accuracy of a PCP diagnosis based on MTP1 arthritis compared with synovial fluid analysis of MSU in 159 patients, of whom 118 (74.2 percent) had MSU crystals at baseline.34 The patients who did not have MSU crystals at baseline underwent a series of additional tests: 10 were diagnosed with a different rheumatic disease, and 31 received the diagnosis of unspecified monoarthritis. All of these patients were followed for at least 1 year; during this followup period, 5 additional patients tested positive for MSU crystals and were then classified as having gout, 12 fulfilled the criteria for a different rheumatic disease (3 osteoarthritis, 2 rheumatoid arthritis, 1 psoriatic arthritis, 1 calcium pyrophosphate deposition disease, 4 other types of arthritis, 1 bunion) and 24 were given the diagnosis of an unspecified monoarthritis (during a subsequent 5-year followup,19 died). The PCP diagnosis based on MTP1 monoarthritis had a sensitivity of 99% and a specificity of 8%, (PPV 0.79, NPV 0.75). The authors concluded that this clinical sign was a promising predictor of gout but not entirely reliable (as at least 20 percent of patients with MTP1 arthritis were incorrectly diagnosed with gout).

##### Effect of Duration of Symptoms on the Accuracy of Gout Diagnoses Based on Clinical Signs and Symptoms

No studies tested the effect of duration of symptoms (time since beginning of flare) on the accuracy of gout diagnoses based on clinical signs and symptoms.

#### Studies Assessing DECT To Diagnose Gout

##### Comparative Accuracy

We identified three original studies that compared the use of DECT for gout diagnosis to a reference standard and enrolled only patients suspected of having gout.18, 28, 30 We also identified one 2014 systematic review comparing DECT and ultrasound for the classification of gout.45 The study details are described in Table 3.

Table 3 Studies assessing the accuracy of DECT to diagnose gout

Author, Year Country Practice Setting | Population n, Putative Diagnosis,Mean Age, % Female | Test Components/Reference Standard | Outcome Measures and Findings | Conclusions and Other Comments
Huppertz 2014^30^ Germany 1 academic rheumatology department | 60 consecutive patients with suspected gout (gout (n=39); remainder: rheumatoid arthritis (n=6); psoriatic arthritis (n=4); undifferentiated oligoarthritis (n=3); chondrocalcinosis (n=2); osteoarthritis (n=2); ankylosing spondylitis, undifferentiated tissue disease, Lyme disease, hydroxyapatite deposition disease (n=1, respectively) Mean age: 62 %female: 18% | Gout suspects 39 diagnosed with gout: Polarization microscopy of synovial fluid (n=18/39 = 46%) OR Positive Janssens Score by rheumatologist (≥8 out of a maximum of13 points) incorporating serum uric acid level (>350micromol/L; 3.5 points), first MTP joint involvement (2.5 points), gender (male, 2 points), previous patient-reported arthritis attack (2 points), cardiovascular diseases (1.5 points), joint redness and onset within 1 day (0.5 points) (n=21/39 = 54%) | Sensitivity, Specificity, Positive Predictive Value, Negative Predictive Value of DECT and US | For gout diagnosis: DECT Sensitivity: 84.6% DECT Specificity: 85.7%% US Sensitivity: 100% US Specificity: 76.2% DECT Pos. Predictive Val.: 91.7% DECT Neg. Predictive Val.: 75.0% US Pos. Predictive Val.: 88.6% US Neg. Predictive Val.: 100% All patients with false-positive DECT were negative in US; all patients with false-positive US were negative in DECT. Comparing 18 MSU+ positive gout patients and 21 patients with other rheumatic disease: DECT Sensitivity: 83.3% US Sensitivity: 100% DECT Pos. Predictive Val.: 83.3% US Pos. Predictive Val.: 78.3% DECT Neg. Predictive Val.: 85.7% US Neg. Predictive Val.: 100% Authors conclude that DECT provides better differential diagnosis than US Data provided on detection of crystals by joint (KQ1b?)
Bongartz 2014^28^ US 1 academic rheumatology department | Accuracy study: 81 patients (40 with acute gout; 41 other) Diagnostic yield study: 30 patients with ambiguous findings (tendonitis but MSU- [22] or inadequate synovial fluid [8]) Mean age: 62.1 (gout); 58.7 (non-gout) %female: 9% (gout); 29% (non-gout) | Polarizing and electron microscopy of synovial fluid | DECT Sensitivity and Specificity Adverse events | Accuracy study: Interobserver Kappa for polarizing microscopy= 0.93 Sensitivity = 90% Specificity = 83% Diagnostic yield study: Patients with inflammatory arthritis + no synovial crystals n = 30; - In this group, DECT negative n = 16; - In this group, DECT positive n = 14; - In DECT positive group, US guided aspiration positive n = 11/12; - In DECT positive group, US guided aspiration negative n = 1/12 (since 2 declined aspiration); - Specificity=92%; Study reports no adverse events from DECT of synovial fluid aspiration to analyze MSU crystals
Glazebrook 2011^18^ US 1 academic or rheumatology department | 94 gout suspects, of whom 43 underwent attempted joint aspiration and 31 patients had successful aspiration (12 crystal-positive; 19 crystal-negative); Mean age: n/a %female: n/a | Reference standard: Joint aspiration for uric acid crystals | Accuracy, Sensitivity, Specificity, and Interobserver agreement of DECT (two readers) | Readers 1 and 2 had no false negative findings for uric acid through DECT. DECT Sensitivity = 100% DECT Specificity (Reader1) = 89% DECT Specificity (Reader2) = 79% Interobserver agreement K = 0.87
Ogdie 2014^45^ Systematic review of gout diagnosis in primary care settings | Inclusion criteria: studies comparing diagnostic performance of X-Ray, MRI, US, CT or DECT in gout; presence of non-gout control group; gout confirmation through synovial fluid aspiration. Exclusion criteria: use of clinical criteria or physician or patient reports instead of MSU crystal presence; lack of control or comparison group; cases with asymptomatic hyperuricemia; not enough information to calculate sensitivity and specificity | Joint aspiration for uric acid crystals | Sensitivity and Specificity of: Double-Contour Sign (DCS) on Ultrasound; Ultrasound of Tophus; DECT. | Ultrasound DCS Sensitivity (pooled) = 83% Ultrasound DCS specificity (pooled) = 76% Ultrasound tophus sensitivity (pooled) = 65% Ultrasound tophus specificity (pooled) = 80% DECT sensitivity (pooled) = 87% DECT specificity (pooled)

ACR = American College of Rheumatology; ARA = American Rheumatism Association; AUC = area under the curve; BMI = body mass index; CGD = clinical gout diagnosis; CI = confidence interval; CRP = c-reactive protein; CVD = cardiovascular disease; GFR = glomerular filtration rate; HTN = hypertension; LR = likelihood ratio; MSU = monosodium urate; MTP = metatarsophalangeal; OA = osteoarthritis; NPV = negative predictive value; NY = New York; PCP = primary care physician; SA = septic arthritis; SD = standard deviation; US = ultrasound; VA = Veterans Administration

A 2011 U.S. study used DECT to assess 94 consecutive patients with suspected gout (in each case, the most painful joint was studied). Of the 94 patients, 31 subsequently underwent successful joint aspiration and assessment for MSU crystals: 12 tested positive for uric acid crystals in the aspirated joint and 19 were MSU-negative (the final diagnoses for the latter patients were not revealed). Two blinded radiologists read the images, with a resulting sensitivity of 100% and specificities of 89% and 79% (K=0.87). For several patients whose DECT findings were initially thought to be false positives based on their MSU analysis, clinicians determined that the DECT findings agreed with diagnoses of gout based on clinical algorithms (which increased the specificity to 100%and 88% for the two readers, respectively. On the basis of these findings, the authors concluded that DECT is a sensitive and reproducible method for uric acid detection in multiple anatomical sites, including several atypical sites for gout and that DECT discriminated calcium pyrophosphate from MSU crystals. As a side note, 5 of the 12 MSU crystal-positive patients had elevated serum urate and the remaining 7 had serum urate within normal limits. Of the MSU crystal-negative patients, 6 had elevated serum urate, and 12 had serum urate within normal limits. Thus the concordance index for a logistic regression model configured with only serum urate as a predictor was poor (c=0.509); however, adding the DECT results to the regression model improved the concordance index to 0.98 (p<0.001).18

A 2014 U.S. study by the same group to determine the diagnostic accuracy of DECT examined 81consecutive patients with suspected gout (joint pain and swelling), 40 of whom were diagnosed with acute gout, and 41 with other arthritic conditions, at a single center.28 As in the previous study, only the most painful joint underwent aspiration and imaging. This assessment showed a sensitivity of 90% and a specificity of 83%. All false-negative DECT scans were patients with acute, recent-onset gout; all false positives had advanced knee osteoarthritis. In a separate study the authors called a diagnostic yield study, they then studied 30 patients with inflammatory arthritis but an unclear diagnosis; 14 of the 30 showed signs of gout on DECT. Of the 14, two refused subsequent joint aspiration, and 11 of the 12 who underwent aspiration were positive for MSU crystals, for a specificity of 92%. The DECT-negative patients did not undergo aspiration, so sensitivity could not be determined for this group. The authors concluded that while DECT is diagnostically useful overall, it has limited sensitivity among patients with acute gout and no prior history of gouty arthritis (i.e., a first flare).

A 2014 study conducted in Germany at a single center comparatively assessed DECT and ultrasound in multiple joints in 60 patients undergoing DECT for suspected gout. Of the 60, 39 were subsequently diagnosed with gout either through polarization microscopic detection of MSU crystals or use of a validated clinical algorithm, and the diagnostic outcomes were compared with those of DECT and of ultrasound.30 They found that DECT gave a sensitivity of 85% and a specificity of 86% (positive predictive value [PPV] 92%, negative predictive value [NPV] 75%). The remaining patients were eventually diagnosed with rheumatoid arthritis, psoriatic arthritis, undifferentiated oligoarthritis, calcium pyrophosphate deposition disease, osteoarthritis, or ankylosing spondylitis, undifferentiated connective tissue disease, Lyme Disease, or hydroxyapatite deposition disease. In addition, 16 of the 39 patients diagnosed with gout had a concomitant inflammatory rheumatic disease (RA, PSA, AS, SLE, systematic sclerosis, and calcium pyrophosphate deposition disease). The comparison of DECT with ultrasound is described below.

A 2014 systematic review (AMSTAR score: 6 of 11)45 pooled the results of two of our included studies,18, 28 and one additional, case-control, study (i.e., enrolled only confirmed gout patients). The pooled sensitivity and specificity for the three DECT studies were 0.87 (95% CI, 0.79, 0.93) and 0.84 (0.75, 0.90), respectively.

##### Effect of Test Accuracy on Clinical Decisionmaking, Clinical Outcomes and Complications, and Patient Centered Outcomes

No studies were identified that tested the effects of the accuracy of gout diagnoses based on DECT on clinical decisionmaking (treatment decisions or decisions to conduct further testing), clinical outcomes, or patient centered outcomes.

##### Effect of Affected Joint Site(s) and Number of Joints on the Diagnostic Accuracy of DECT

No studies were identified that tested the effects of the joint site affected or the number of joints affected on the accuracy of DECT.

##### Effect of Duration of Symptoms on the Accuracy of Gout Diagnoses Based on DECT

No studies tested the effect of duration of symptoms (time since beginning of flare) on the accuracy of gout diagnoses based on DECT.

#### Studies Assessing the Accuracy of Ultrasound To Diagnose Gout

##### Comparative Accuracy

We identified four original prospective or cross-sectional studies that assessed the accuracy of ultrasound to diagnose gout in patients suspected of having gout; the reference standards adopted in these studies were either MSU crystal analysis, the use of a diagnostic clinical algorithm, or a combination of the two.30, 35, 36, 38 These studies are described in Table 4. The QUADAS ratings for each of these studies are presented in Table 5. We also identified two recent systematic reviews on the use of ultrasound to diagnose gout.43, 45

Table 4 Summary of studies reporting on the use of ultrasound for diagnosis of gout

Author, Year Country Practice Setting | Population n, Putative diagnosis, Mean Age, % Female | Criteria/Reference Standard | Joints | US Characteristics | Outcomes | Author Conclusions Comments
Lamers-Karnebeck, 2014^36^ Netherlands Academic Rheumatology Clinic | Monoarthritis (n=54) 28 gout dx (26 MSU+) 7 CPPD 19 non-crystal arthritis Mean age: MSU+: 63.5 (55.5–69.5) MSU-: 55.0 (41.8–63.5) % female: MSU+: 4% MSU-: 86.6 | Aspiration Clinical Not well described | 6 joints Target, Knee, MTP (bilateral) | Any US Finding Double Contour Snow Storm Tophi | [underlined: Any abnormality]: Sensitivity:96 Specificity:68 PPV:74 NPV:95 LR+:2.99 LR-:0.06 [underlined: Double contour sign]: Sensitivity:77 Specificity: 75 PPV: 74 NPV: 78 LR+: 3.08 LR-: 0.31 [underlined: Snow storm]: Sensitivity:38 Specificity: 86 PPV: 71 NPV: 60 LR+: 2.6 LR-: 0.72 [underlined: Tophus Presence]: Sensitivity: 19 Specificity: 93 PPV: 71 NPV: 55 LR+:2.69 LR-: 0.87 | Authors conclude that US, if done by skilled diagnosticians has a useful place as part of early gout diagnostic algorithm. DCS is seen in 77% of gout patients and 25% of non-gout patients. Comment: Best for purpose of utility of diagnosis
Lai, 2011^35^ Taiwan Hospital rheumatology department | Monoarthritis (n=80) 34 (52 joints) MSU+ 46 (52 joints) MSU- Mean age: 69.4 (range 52.8-80.8) % female: 17.6% (gout) 52.2% (non-gout) | Aspiration Clinical criteria (joint swelling, heat, tenderness) | Target Joint | Double Contour Snow Storm Tophi Bony erosion PDUS | [underlined: Double contour sign (DCS)]: Sensitivity: 36.8 Specificity: 97.3 PPV: 93.3 NPV: 60 LR+: 13.63 LR-: 0.65 [underlined: Bright Stippled foci (BSF):] Sensitivity: 76.9 Specificity: 65.4 PPV: 69 NPV: 73.9 LR+: 2.22 LR-: 0.35 [underlined: DCS OR BSF]: Sensitivity: 86.5 Specificity: 63.5 PPV: 70.3 NPV: 82.5 LR+:2.37 LR-: 0.21 [underlined: DCS AND BSF]: Sensitivity: 23.7 Specificity: 100 PPV: 100 NPV: 56.1 LR+: LR-: 0.76 | Analysis was at the joint level, not patient Authors conclude that presence of both DCS and BSF is indicative of gout. Hyperechoic aggregations, bone erosion, and synovial vascularity did not distinguish gout from non-gout arthritis.
Huppertz, 2014^30^ Germany Academic rheumatology department | 60 patients with suspected gout: Gout (39) RA (6) PsA(4) Other (8) CPPD (2) Hydroxyapatite disease (1) Mean age: 62[11.3] (range: 36-82) % female: 18.3 | Clinical impression: Crystal +/- clinical score (Janssens≥8 considered alternate standard of reference for gout) | Foot/ankle Knee Hand/wrist Elbow | Hyperechoic findings Double contour sign | US: Sensitivity: 100 Specificity:76.2 PPV: 88.6 NPV:100 LR+: 4.20 LR-: 0 DECT: Sensitivity: 84.6 Specificity:85.7 PPV: 91.7 NPV: 75 LR+: 5.92 LR-: 0.18 | Study compares US with DECT: US has lower specificity than DECT for gout but is more sensitive to small MSU crystal deposits
Rettenbacher, 2008^38^ Austria Academic radiology, rheumatology, and internal medicine departments | 105 patients with clinical suspicion of gout Mean age 59 (range: 31-89) % female: 12% Gout(55) Another disease (31) No definitive diagnosis (19, excluded) | Aspiration of synovial fluid and MSU crystal analysis (30 patients) or characteristic clinical and lab findings (56 patients, not further described) | Multiple sites including MTP1, PIP joint (foot and hand), DIP joint, tarsus, ankle, knee, MCP joint, Metacarpus, Carpus, elbow, Achilles tendon, tibialis anterior tendon, ligamentum patellae, extensor tendons, tendons of third finger | Bright stippled foci Hyperechoic areas Bone erosions Hyperechoic streaks Hypervascularization | US: [underlined: BSF]: Sensitivity: 80 Specificity:75 PPV: 85 NPV: 69 LR+: 3.2 LR-:0.27 [underlined: Hyperechoic areas]: Sensitivity: 79 Specificity: 95 PPV: 96 NPV: 73 LR+:15.8 LR-:0.22: [underlined: At least one of the above +]: Sensitivity: 96 Specificity: 73 PPV: 86 NPV: 91 LR+: 3.56 LR-:0.05 [underlined: Bone erosions]: Sensitivity: 24 Specificity:69 PPV: 57 NPV: 34 LR+:0.77 LR-:1.10 [underlined: Hyperechoic streaks]: Sensitivity: 80 Specificity:49 PPV: 1.57 NPV: 0.41 Hypervascularization Sensitivity: 94 Specificity:53 PPV: 77 NPV: 84 LR+: 2.00 LR-: 0.11 X-ray: [underlined: Opacification]: Sensitivity: 26 Specificity: 97 PPV: 93 NPV:43 LR+: 8.67 LR-: 0.76 [underlined: Bone erosions]: Sensitivity: 20 Specificity: 95 PPV: 87 NPV:41 LR+: 4.00 LR-: 0.84 [underlined: Osseous Apposition]: Sensitivity: 5 Specificity: 100 PPV: 100 NPV: 38 LR+: LR-: 0.95 [underlined: At least one positive sign]: Sensitivity: 31 Specificity: 93 PPV: 89 NPV: 44 LR+: 4.43 LR-: 0.74 | US compared with plain x-ray For US, alone, BSF and hyperechoic areas are most suggestive of gout. X-ray is less specific but much more sensitive for diagnosing gout than is US

AH = asymptomatic hyperuricemia; BSF = [underlined: b]right stippled foci; CPPD = calcium pyrophosphate deposition (formerly pseudogout); DECT = dual-energy computed tomography; DCS = double-contour sign; LR = likelihood ratio; MSU = monosodium urate; MTP = metatarsophalangeal; NPV = negative predictive value; PPV = positive predictive value; PsA = psoriatic arthritis; RA = rheumatoid arthritis; US = ultrasound.

A 2008 study conducted in Austria with a population of 86 consecutive patients with clinical suspicion of gout compared ultrasound with plain x-ray and with a reference standard of MSU assessment (30 patients) or a diagnostic clinical algorithm (56 patients).38 The authors assessed the sensitivity and specificity for a number of ultrasound indicators, included bright stippled foci (BSF, which is hyperechoic deposition in the synovium), hyperechoic areas, at least one of the former two, bone erosions, and hyperechoic streaks. BSF and hyperechoic areas alone had comparable sensitivity (80%, 79%), whereas the specificity of BSF was relatively low (75%) compared with that of hyperechoic areas (95%). The presence of at least one positive sign (BSF or hyperechoic areas) had a sensitivity of 96% and a specificity of 73%. Compared with ultrasound, plain x-ray was much less sensitive but comparable in specificity (31%/93%). Bony erosions detected by ultrasound or plain x-ray had equally poor sensitivity but widely varying specificity (69%-95%). The patients in the study had clinical involvement at a number of different sites (primarily the MTP1 joint and the knee); the authors did not attempt to estimate the effect of site or number of sites involved in the sensitivity or specificity of the test. Patients determined not to have gout had osteoarthritis, rheumatoid arthritis, psoriatic arthritis, septic arthritis, calcium pyrophosphate deposition disease, chondrocalcinosis, or no conclusive diagnosis.

A 2011 study conducted in a Taiwan hospital enrolled 80 patients with acute monoarthritis or oligoarthritis who underwent ultrasound-guided joint aspiration (recruitment method not described). Ultrasound of the target joint was compared with ultrasound-guided joint aspiration and fluid analysis for MSU and a diagnostic clinical algorithm.35 Of the 80 patients, 34 (representing 52 joints) were MSU crystal-positive. Images were assessed for double contour sign (DCS, hyperechoic deposition on the surface of the articular hyaline cartilage), BSF, snow storm, tophi, and bony erosion. The DCS alone had a sensitivity of 36.8% and a specificity of 97.3% (PPV 93; NPV 60); BSF alone had a sensitivity of 76.9% and specificity of 65.4%. The presence of either DCS or BSF had a sensitivity of 86.5% and a specificity of 63.5% (PPV 70 and NPV 82); whereas the DCS combined with the BSF had a sensitivity of 23.7 (NPV 56.1) and a specificity and PPV of 100. Patients who were MSU crystal-negative met criteria for calcium pyrophosphate deposition disease (5), septic arthritis (14), rheumatoid arthritis (4), osteoarthritis (4), and other inflammatory arthritis (18). Interobserver correlations were excellent for the DCS (K=0.86) and good for BSF (0.73).

A 2014 study conducted in the Netherlands enrolled all 54 patients referred to an academic hospital outpatient department with monoarthritis but no further diagnosis.36 Patients underwent ultrasound of the affected joint and five additional joints (knees, MTP joints, and any additional target joint of interest, bilaterally) for a total of six images; the images were examined for DCS, snow storm, tophi, and any other ultrasound finding. Assessments were compared with the results of joint aspiration and MSU analysis in all but two patients or the Janssens diagnostic clinical algorithm31 in the remaining two patients. The finding of a DCS had a sensitivity of 77% and a specificity of 75% (PPV 74%, NPV 78%; LR+ 3.08, LR- 0.31); inclusion of any sign of abnormality had a sensitivity of 96% and a specificity of 68% (PPV 74%, NPV 95%' LR+2.99, LR- 0.06); snowstorm had a sensitivity of 38% and a specificity of 86% (PPV 71%, NPV 60%); indication of a tophus had a sensitivity of 19% and a specificity of 93%. The inter-rater reliability improved with the number of patients (kappa increased from 0.44 to 0.67 for the DCS).

A 2014 study conducted in Germany compared the findings of ultrasound with those of DECT30 (DECT findings described above) among 60 gout suspects. The standard of reference was MSU and the Janssens diagnostic clinical algorithm. The assessment of hyperechoic findings and DCS had a sensitivity of 100% and specificity of 76% (PPV 89, NPV 100). The comparison of ultrasound with DECT showed that ultrasound is more sensitive and less specific than DECT for the diagnosis of gout and is particularly useful for patients with inconclusive joint aspiration, other co-occuring rheumatic diseases, and ambivalent findings. In a joint-based evaluation, ultrasound was more sensitive than DECT for gout diagnosis; however, differentiating between calcium pyrophosphate deposition disease and gout at the wrist is challenging with ultrasound.

Two systematic reviews assessed studies of ultrasound for gout. A 2012 systematic review by Chowalloor (AMSTAR score: 4 of 11)43 reviewed the results of 18 studies (1975 to 2012) on the use of ultrasound for management (and secondarily, diagnosis) of gout and hyperuricemia. Only one of these studies was included in the present review;38 the remaining studies were excluded from our analysis either because they included only patients with definitive gout diagnoses, included only patients with chronic gout in the intercritical period, or included primarily patients with asymptomatic hyperuricemia. The review, which did not include a meta-analysis, concluded that the DCS is specific for the diagnosis of gout, and that ultrasound can track changes in joint architecture, e.g., development of tophi.

A 2014 systematic review by Ogdie (AMSTAR score: 6 of 11)45 on the use of ultrasound (and DECT) for gout classification pooled the results of five studies on the use of ultrasound, one of which was included in the present review 36 (the remaining four studies were excluded from our analysis because the populations consisted of patients with prior gout diagnoses). For the DCS, the review reported a pooled sensitivity of 83% (95% CI 72%, 91%) and a specificity of 76% (68%, 83%). For tophus detection, the pooled sensitivity was 65% (34%, 87%) and the pooled specificity was 87% (79%, 93%).

##### Effect of Test Accuracy on Clinical Decisionmaking, Clinical Outcomes and Complications, and Patient Centered Outcomes

No studies were identified that tested the effects of the accuracy of gout diagnoses based on ultrasound on clinical decisionmaking (treatment decisions or decisions to conduct further testing), clinical outcomes, or patient centered outcomes.

##### Effect of Affected Joint Site(s) and Number of Joints on the Diagnostic Accuracy of Ultrasound

No studies were identified that tested the effects of the joint site affected or the number of joints affected on the accuracy of diagnosis by ultrasound.

##### Effect of Duration of Symptoms on the Accuracy of Gout Diagnoses Based on Ultrasound

No studies tested the effect of duration of symptoms (time since beginning of flare) on the accuracy of gout diagnoses based on ultrasound.

## KQ1d Does the accuracy of synovial fluid aspiration and crystal analysis Differ by (i) the type of practitioner who is performing the aspiration and (ii) the type of practitioner who is performing the crystal analysis?

The question we were asked to answer was whether the accuracy of gout detection by synovial fluid aspiration and crystal analysis differs by (i) the type of practitioner who is performing the aspiration and (ii) the type of practitioner or technologist who is performing the crystal analysis.

### Key Points

- Agreement among medical and ancillary health personnel examining synovial fluid using polarizing microscopy for detection of MSU crystals appears to be poor, but it is unclear whether the experience and training of analysts are a factor. No studies examined the effect of the type of practitioner performing fluid aspiration on the ability to obtain a sample for analysis. Because of the small number of studies identified, the strength of evidence for definitive influential factors is insufficient.

### Description of Included Studies

We identified two original studies that addressed the question of whether the results of MSU analysis are affected by the type of practitioner or training. We identified no studies that addressed the question of how MSU assessment is affected by the person performing the joint aspiration. A 1989 study compared the accuracy of an experienced rheumatologist, several medical residents, and several technicians in identifying MSU and calcium pyrophosphate crystals suspended in synovial fluid using polarizing microscopy. A 2014 study retrospectively audited medical records of two Korean academic medical centers to assess factors associated with false negative synovial fluid MSU results and focused on the personnel performing the analysis and several other factors.37

### Detailed Synthesis

A 1989 study conducted in a United Kingdom academic rheumatology department compared the ability of a small number of technicians and clinicians to conduct crystal detection.29 Synovial fluid samples were aspirated from the knee or shoulder of 13 patients with clinical diagnoses of rheumatoid arthritis or osteoarthritis (the person conducting the aspiration was not described). Purified MSU, calcium pyrophosphate, and basic calcium phosphate crystals prepared according to published methods were suspended in the fluid samples to achieve a range of concentrations that would be visualized as occasional crystals seen in a microscopic field, 10 MSU or calcium pyrophosphate crystals, or 5 phosphate crystals per microscopic field. The individuals whose performances were compared included two lab technicians (one with specialty training in crystal identification), an inexperienced physician, two rheumatology residents, and an experienced rheumatology attending physician. At the beginning of the exercise, all were shown microscopic examples of each type of crystals. Each observer was then tested on 82 slides. The sensitivities for MSU ranged from 65% to 76% (mean 69%) and the specificities ranged from 93% to 100% (mean 97%): The trained technician and the inexperienced physician's assessments showed the highest sensitivity 73% and 76%), whereas one of the residents and the experienced attending had the highest specificity (100%). For calcium pyrophosphate crystal detection, the performance varied far more. The sensitivity ranged from 60% to 93% (mean 82%), and the specificity ranged from 61% to 98% (mean 78%): The experienced attending had by far the lowest—and the inexperienced physician had the highest—sensitivity, whereas one of the residents had by far the lowest—and the experienced attending had the highest—specificity.

A 2014 study in South Korea aimed to assess the rate of MSU detection and factors associated with false-negative findings. The researchers examined retrospective data from 179 patients (94.4 percent male, average age at diagnosis 62.6[16.4], 43.9 percent were experiencing their first attack) seen in two South Korean academic rheumatology departments.37 The charts of patients who underwent synovial fluid analysis for presumed acute gout between 1999 and 2011 were audited; patients were excluded if they were diagnosed with intercritical gout without acute symptoms, pseudogout, osteoarthritis, or both septic arthritis and gout. Patients were classified as having acute gout based on ACR criteria. MSU analysis at both hospitals was conducted either by lab medicine personnel (34.3 percent), by Rheumatology Department personnel (3.5 percent), or both (62.1 percent), at both hospitals. Of 198 samples analyzed for the 179 patients, 78.8 percent were crystal-positive, and 21.2 percent were negative. The detection rate for samples examined by the lab medicine departments was 51.8 percent, compared with 93.8 percent for the rheumatologists. When agreement was assessed for samples analyzed by both departments, the detection rate was 93.5 percent for rheumatologists and 51.2 percent for lab medicine, for a kappa of 0.108. Examination by lab medicine was the most significant variable associated with crystal-negative synovial fluid analysis (OR 36.996, 95% CI 9.731, 140.648). In addition, multivariate analysis showed that the time interval from attack onset to arthrocentesis was the only factor significantly associated with the likelihood of negative crystal findings (4.5±5.1 days for negative findings vs. 3.0±2.8 days for positive findings; OR 1.105, 95% CI 1.004, 1.216; p=0.042). Analysis by laboratory medicine was thought to be associated with a longer lag time than analysis by the Rheumatology departments.

## Key Question 2 What are the adverse effects (including pain, infection at the aspiration site, radiation exposure) or harms (related to false positives, false negatives, indeterminate results) associated with tests used to diagnose gout?

### Key Points

- Considering potential adverse effects that might be associated with diagnostic tests for gout, including pain, infection (at the aspiration site), or the short- or long-term effects of radiation exposure, no studies documented any adverse events associated with diagnostic tests for gout in any studies included in this report. The strength of evidence for this conclusion is low, based on only one study that reported no adverse events associated with joint fluid aspiration for MSU analysis or DECT and no studies that reported on adverse events associated with ultrasound or clinical examinations.
- Missed diagnosis or delayed diagnosis of acute gout (failure to find MSU crystals in synovial fluid) was reported in a retrospective two-center study to be associated with a longer interval between the onset of attack and joint aspiration. A negative MSU finding was associated with higher risk for undergoing arthroscopic drainage, longer hospital stay, and delays in antiinflammatory treatment. The strength of evidence for this conclusion is insufficient.

### Description of Included Studies

One study was identified that assessed adverse effects associated with tests used to diagnose gout.28 This study reported no adverse events associated with aspiration of synovial fluid for MSU analysis or the use of DECT.

One study examined the outcomes of delayed diagnosis or misdiagnosis of gout in two academic medical centers in South Korea.37

### Detailed Synthesis

A 2014 study described earlier that examined the accuracy of DECT for diagnosis of gout in 81 patients noted in passing that neither aspiration of synovial fluid for MSU assessment nor DECT were associated with any adverse events.28

A 2014 study conducted retrospective medical chart review to examine factors associated with failure to diagnose gout and also compared treatment outcomes between those who had a positive finding for MSU crystals and those who did not.37 This study, described above, examined retrospective data from 179 patients (all meeting ACR criteria, 94.4 percent male, average age at diagnosis 62.6[16.4], 43.9 percent experiencing their first attack) seen in two South Korean academic rheumatology departments. They found no differences in the proportions of MSU crystal-negative and MSU crystal-positive patients who eventually received NSAIDs or colchicine, but MSU crystal-negative patients were less likely than MSU crystal-positive patients to receive intra-articular glucocorticoid injections (7.1 percent vs. 21.8 percent, p=0.043). In addition, MSU crystal-negative patients underwent emergency arthroscopic surgery and drainage more frequently than MSU crystal-positive patients (26.2 percent vs. 3.8 percent, p=4.48×10^-6^, chi-squared test), based on a suspicion of septic arthritis, in spite of negative cultures and visible MSU deposits in the joints. A first episode of monoarthritis (OR 6.954, 95% CI 1.577, 20622, p=0.01), negative findings for MSU crystal analysis (OR 23.760, 95% CI 4.451, 126.843 p=2.10×10^-4^), and fever (OR 15.123, 95% CI 2.739, 83.503, p=0.002) were independent risk factors for surgery. Patients undergoing arthroscopic surgery and drainage based on suspected septic arthritis had a significantly longer hospital stay than the 19 newly diagnosed gout patients hospitalized for medical treatment (18.4±12.6 days vs. 8.9±6.7 days, p=0.007), and patients undergoing arthroscopic surgery received anti-inflammatory drugs significantly later than those who received only medical treatment (5.0±3.4 days vs. 0.4±0.8 days, p=8.74×10^-5^).