# References

1 Zhu Y, Pandya BJ, Choi HK. Prevalence of gout and hyperuricemia in the US general population: the National Health and Nutrition Examination Survey 2007-2008. Arthritis Rheum. Oct. 2011;63(10):3136-41. [pmid: 21800283].
2 Li C, Martin BC, Cummins DF, et al. Ambulatory resource utilization and cost for gout in United States. Am J Pharm Benefits. March/April. 2013;5(2):e46-e54.
3 Doghramji PP, Wortmann RL. Hyperuricemia and gout: new concepts in diagnosis and management. Postgrad Med. Nov. 2012;124(6):98-109. [pmid: 23322143].
4 Wallace SL. Hyperuricemia in the diagnosis of gout. J Gen Intern Med. Mar-Apr. 1989;4(2):178-9. [pmid: 2651605].
5 Singh JA, Reddy SG, Kundukulam J. Risk factors for gout and prevention: a systematic review of the literature. Curr Opin Rheumatol. Mar. 2011;23(2):192-202. [pmid: 21285714].
6 Hamburger M, Baraf HS, Adamson TC 3rd, et al. 2011 Recommendations for the diagnosis and management of gout and hyperuricemia. Postgrad Med. Nov. 2011;123(6 Suppl 1):3-36. [pmid: 22156509].
7 Harrold LR, Mazor KM, Negron A, et al. Primary care providers' knowledge, beliefs and treatment practices for gout: results of a physician questionnaire. Rheumatology (Oxford). Sep. 2013;52(9):1623-9. [pmid: 23620554].
8 Owens D, Whelan B, McCarthy G. A survey of the management of gout in primary care. Ir Med J. 2008;101(5):147-9. [pmid: 18624262].
9 Khosla S, Thiele R, Baumhauer JF. Ultrasound guidance for intra-articular injections of the foot and ankle. Foot Ankle Int. Sep. 2009;30(9):886-90. [pmid: 19755074].
10 Hasselbacher P. Variation in synovial fluid analysis by hospital laboratories. Arthritis and Rheumatism. 1987;30(6):637-42. [pmid: 3606682].
11 Schumacher HR Jr., Sieck MS, Rothfuss S, et al. Reproducibility of synovial fluid analyses. A study among four laboratories. Arthritis Rheum. Jun. 1986;29(6):770-4. [pmid: 3718565].
12 McGill NW, York HF. Reproducibility of synovial fluid examination for crystals. Aust N Z J Med. Oct. 1991;21(5):710-3. [pmid: 1759919].
13 Segal JB, Albert D. Diagnosis of crystal-induced arthritis by synovial fluid examination for crystals: lessons from an imperfect test. Arthritis Care Res. Dec. 1999;12(6):376-80. [pmid: 11081008].
14 Graf SW, Buchbinder R, Zochling J, et al. The accuracy of methods for urate crystal detection in synovial fluid and the effect of sample handling: a systematic review. Clin Rheumatol. Feb. 2013;32(2):225-32. [pmid: 23138881].
15 Perez-Ruiz F, Carmona L, Yebenes MJG, et al. An audit of the variability of diagnosis and management of gout in the rheumatology setting: the Gout Evaluation and Management Study. J Clin Rheumatol. Oct. 2011;17(7):349-55. [pmid: 21946457].
16 Malik A, Schumacher HR, Dinnella JE, et al. Clinical diagnostic criteria for gout: comparison with the gold standard of synovial fluid crystal analysis. J Clin Rheumatol. Feb. 2009;15(1):22-4. [pmid: 19125136].
17 Dalbeth N, Fransen J, Jansen TL, et al. New classification criteria for gout: a framework for progress. Rheumatology (Oxford). Oct. 2013;52(10):1748-53. [pmid: 23611919].
18 Glazebrook KN, Guimaraes LS, Murthy NS, et al. Identification of intraarticular and periarticular uric acid crystals with dual-energy CT: initial evaluation. Radiology. Nov. 2011;261(2):516-24. [pmid: 21926378].
19 Khanna D, Fitzgerald JD, Khanna PP, et al. 2012 American College of Rheumatology guidelines for management of gout. Part 1: systematic nonpharmacologic and pharmacologic therapeutic approaches to hyperuricemia. Arthritis Care Res (Hoboken). 2012;64(10):1431-46. [pmid: 23024028].
20 Khanna D, Khanna PP, Fitzgerald JD, et al. 2012 American College of Rheumatology guidelines for management of gout. Part 2: therapy and antiinflammatory prophylaxis of acute gouty arthritis. Arthritis Care Res (Hoboken). 2012;64(10):1447-61. [pmid: 23024029].
21 Whiting P, Westwood M, Beynon R, et al. Inclusion of methodological filters in searches for diagnostic test accuracy studies misses relevant studies. J Clin Epidemiol. Jun. 2011;64(6):602-7. [pmid: 21075596].
22 Zhang W, Doherty M, Pascual E, et al. EULAR evidence based recommendations for gout. Part I: diagnosis. Report of a task force of the Standing Committee for International Clinical Studies Including Therapeutics (ESCISIT). Ann Rheum Dis. Oct. 2006;65(10):1301-11. [pmid: 16707533].
23 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. Oct. 18. 2011;155(8):529-36. [pmid: 22007046].
24 Santaguida PL, Riley CM, Matchar DB. Assessing risk of bias as a domain of quality in medical test studies. Methods Guide for Medical Test Reviews. AHRQ Publication No. 12-EHC017. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. Chapters available at www.effectivehealthcare.ahrq.gov/reports/final.cfm.
25 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
26 Methods Guide for Medical Test Reviews. AHRQ Publication No. 12-EHC017. Agency for Healthcare Research and Quality. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. Chapters available at www.effectivehealthcare.ahrq.gov/reports/final.cfm.
27 Atkins D, Chang S, Gartlehner G, et al. Assessing the applicability of studies when comparing medical interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at www.effectivehealthcare.ahrq.gov.
28 Bongartz T, Glazebrook KN, Kavros SJ, et al. Dual-energy CT for the diagnosis of gout: an accuracy and diagnostic yield study. Ann Rheum Dis. Jun. 2015;74(6):1072-7. [pmid: 24671771].
29 Gordon C, Swan A, Dieppe P. Detection of crystals in synovial fluids by light microscopy: sensitivity and reliability. Ann Rheum Dis. Sep. 1989;48(9):737-42. [pmid: 2478085].
30 Huppertz A, Hermann KG, Diekhoff T, et al. Systemic staging for urate crystal deposits with dual-energy CT and ultrasound in patients with suspected gout. Rheumatol Int. Jun. 2014;34(6):763-71. [pmid: 24619560].
31 Janssens HJEM, Fransen J, Van De Lisdonk EH, et al. A diagnostic rule for acute gouty arthritis in primary care without joint fluid analysis. Arch Intern Med. 2010;170(13):1120-6. [pmid: 20625017].
32 Janssens HJEM, Janssen M, Van De Lisdonk EH, et al. Limited validity of the American College of Rheumatology criteria for classifying patients with gout in primary care. Ann Rheum Dis. 2010;69(6):1255-6. [pmid: 19910298].
33 Kienhorst LB, Janssens HJ, Fransen J, et al. The validation of a diagnostic rule for gout without joint fluid analysis: a prospective study. Rheumatology (Oxford). Apr. 2015;54(4):609-14. [pmid: 25231179].
34 Kienhorst LB, Janssens HJ, Fransen J, et al. Arthritis of the first metatarsophalangeal joint is not always gout: a prospective cohort study in primary care patients. Joint Bone Spine. Jul. 2014;81(4):342-6. [pmid: 24468668].
35 Lai KL, Chiu YM. Role of ultrasonography in diagnosing gouty arthritis. J Med Ultrasound. March. 2011;19(1):7-13. http://dx.doi.org/10.1016/j.jmu.2011.01.003.
36 Lamers-Karnebeek FB, Van Riel PL, Jansen TL. Additive value for ultrasonographic signal in a screening algorithm for patients presenting with acute mono-/oligoarthritis in whom gout is suspected. Clin Rheumatol. Apr. 2014;33(4):555-9. [pmid: 24510062].
37 Park JW, Ko DJ, Yoo JJ, et al. Clinical factors and treatment outcomes associated with failure in the detection of urate crystal in patients with acute gouty arthritis. Korean J Intern Med. 2014;29(3):361-9. [pmid: 24851071].
38 Rettenbacher T, Ennemoser S, Weirich H, et al. Diagnostic imaging of gout: comparison of high-resolution US versus conventional X-ray. Eur Radiol. Mar. 2008;18(3):621-30. [pmid: 17994238].
39 Richette P, Clerson P, Bouee S, et al. Identification of patients with gout: elaboration of a questionnaire for epidemiological studies. Ann Rheum Dis. 2014. May. 5. [pmid: 24796335].
40 Taylor WJ, Fransen J, Dalbeth N, et al. Performance of classification criteria for gout in early and established disease. Ann Rheum Dis. 2014. Oct. 28. [pmid: 25351521].
41 Vazquez-Mellado J, Hernandez-Cuevas CB, Alvarez-Hernandez E, et al. The diagnostic value of the proposal for clinical gout diagnosis (CGD). Clin Rheumatol. Mar. 2012;31(3):429-34. [pmid: 21979446].
42 Wallace SL, Robinson H, Masi AT, et al. Preliminary criteria for the classification of the acute arthritis of primary gout. Arthritis Rheum. Apr. 1977;20(3):895-900. [pmid: 856219].
43 Chowalloor PV, Keen HI. A systematic review of ultrasonography in gout and asymptomatic hyperuricaemia. Ann Rheum Dis. May. 2013;72(5):638-45. [pmid: 23291387].
44 Dirken-Heukensfeldt K, Teunissen TAM, van de Lisdonk EH, et al. “Clinical features of women with gout arthritis.” A systematic review. Clinical Rheumatology. Jun. 2010;29(6):575-82. [pmid: 20084441].
45 Ogdie A, Taylor W, Weatherall M, et al. Imaging modalities for the classification of gout: systematic literature review and meta-analysis. Ann Rheum Dis. 2014. Jun. 20. [Epub ahead of print]. [pmid: 24915980].
46 Sivera F, Andres M, Falzon L, et al. Diagnostic value of clinical, laboratory, and imaging findings in patients with a clinical suspicion of gout: a systematic literature review. J Rheumatol Suppl. Sep. 2014;92:3-8. [pmid: 25180122].
47 Sivera F, Andres M, Carmona L, et al. Multinational evidence-based recommendations for the diagnosis and management of gout: integrating systematic literature review and expert opinion of a broad panel of rheumatologists in the 3e initiative. Ann Rheum Dis. Feb. 2014;73(2):328-35. [pmid: 23868909].
48 Berendsen D, Jansen TL, Taylor W, et al. A critical appraisal of the competence of crystal identification by rheumatologists. Ann Rheum Dis. 2014;72(Suppl 3):A981-2.
49 Hamburger MI, Tesser JRP, Skosey JL, et al. Patterns of gout treatment and related outcomes in US community rheumatology practices: the relation between gout flares, time in treatment, serum uric acid level and urate lowering therapy. Arthritis and Rheumatism. 2012;64(Suppl 10):1904.
50 Richette P, Pascual E, Doherty M, et al. Updated EULAR evidence-based recommendations for the diagnosis of gout. Ann Rheum Dis. 2014;(Suppl 2):783-84.
51 Dalbeth N. Management of gout in primary care: challenges and potential solutions. Rheumatology (Oxford). Sep. 2013;52(9):1549-50. [pmid: 23771950].
52 Rigby AS, Wood PH. Serum uric acid levels and gout: what does this herald for the population?. Clin Exp Rheumatol. Jul-Aug. 1994;12(4):395-400. [pmid: 7955603].
53 Lenski M, Scherer MA. Analysis of synovial inflammatory markers to differ infectious from gouty arthritis. Clin Biochem. Jan. 2014;47(1-2):49-55. [pmid: 24177196].
54 Wang C, Zhong D, Liao Q, et al. Procalcitonin levels in fresh serum and fresh synovial fluid for the differential diagnosis of knee septic arthritis from rheumatoid arthritis, osteoarthritis and gouty arthritis. Exp Ther Med. Oct. 2014;8(4):1075-80. [pmid: 25187799].