# Methods

## Criteria for Inclusion/Exclusion of Studies in the Review

This report is based on a systematic search for prospective or cross-sectional studies that assessed the sensitivity and specificity of tests used to diagnose gout, preferably against the gold standard test of joint aspiration and synovial fluid assessment for MSU crystals, in populations of adults 18 years of age or older, suspected of having gout but not previously diagnosed (see Table 1). We also included studies that assessed patient and practitioner factors that affect the diagnostic accuracy of these tests, assessed harms associated with the tests, or examined particular factors that potentially affect the sensitivity or specificity of tests (joints involved and duration of symptoms).

Tests of interest included algorithms comprising clinical or laboratory examination for physical signs, symptoms, and history; serum uric acid, ultrasonography; DECT; and plain radiography. The comparator of primary interest was synovial fluid analysis of MSU crystals using polarized light microscopy. However, if no such studies could be identified for a diagnostic test of interest, studies were also included if some or all of the participants were diagnosed using the American College of Rheumatology criteria for gout diagnosis and classification or another validated set of criteria as the reference standard (comparator).

Studies were excluded if enrolled participants had already been definitively diagnosed with gout prior to enrollment (to ensure that the patient populations were as similar as possible to patients who would be seen in the primary or urgent or emergent care setting), or if the comparator was individual physician opinion or was not identified. Inclusion criteria are further described below in the section entitled PICOTs (Populations, Interventions, Comparators, Outcomes, Timeframes, a framework used in systematic reviews to categorize inclusion and exclusion criteria).

Outcomes of interest were the comparative accuracy of the test results (as measured by the sensitivity and specificity or the positive and negative predictive value of the test in question), intermediate outcomes such as lab and radiographic test results, clinical decisionmaking that resulted from diagnoses, short term clinical (patient-centered) outcomes such as a change in pain and joint swelling that resulted from a diagnosis, and any adverse events (including adverse patient experiences such as pain or infection at the aspiration site, effects of radiation exposure, and the results of a false positive or negative diagnosis) associated with the test. Outcomes are further described below.

Prospective cohort, cross-sectional, and case-control (if needed) studies were included to address Key Question 1 (accuracy of test and factors that affect accuracy). Prospective cohort, cross-sectional, and case control studies, as well as case series of any size and case reports of rare adverse events were included if they addressed Key Question 2 (adverse events or other negative outcomes in individuals undergoing testing).

### PICOTS of Included Studies

Population(s) (KQ1 and 2):

- Adults (18 years and over) presenting with symptoms (e.g., an acute episode of joint inflammation) suggestive of gout, but without a prior gout diagnosis, including the following subgroups:
  ○ Male and female patients
  ○ Patients with longer vs. shorter duration of symptoms
  ○ Patients with comorbidities including hypertension, type 2 diabetes, kidney disease (renal insufficiency)
  ○ Patients with osteoarthritis, septic arthritis, calcium pyrophosphate deposition disease, or previous joint trauma
  ○ Individuals with a family history of gout

Interventions (Index Tests) (KQ1, 2):

- Clinical history and physical exam
- Serum urate assessment
- Ultrasound
- DECT
- Plain x-ray
- Joint aspiration by physicians and synovial fluid analysis using polarizing microscopy (by physicians or laboratory personnel)
- Combinations of these tests as identified in the literature

Comparators (Reference Tests):

- Joint synovial fluid aspiration and microscopic assessment for monosodium urate crystals (KQ1a-c, 2)
- Joint synovial fluid aspiration and microscopic assessment for monosodium urate crystals as performed by a practitioner with a different level of expertise or experience, e.g. rheumatologist, laboratory personnel (KQ1d)

Outcomes:

- Diagnostic accuracy of clinical signs and symptoms, US, DECT, plain radiographs compared with joint aspiration and synovial fluid analysis (KQ1)
  ○ Sensitivity/specificity, true positives/true negatives, area under the curve
  ○ Positive predictive value (PPV), negative predictive value (NPV), positive/negative likelihood ratios (if prevalence known)
- Clinical decisionmaking
  ○ Additional testing
  ○ Pharmacologic/dietary management
- Intermediate outcomes
  ○ Serum urate
  ○ Synovial fluid crystals
  ○ Radiographic or ultrasound changes
- Clinical outcomes
  ○ Pain, joint swelling and tenderness,
  ○ Patient global assessment, and activity limitations (KQ1,2)
- Adverse effects of the tests, including
  ○ Pain, infection, radiation exposure and
  ○ Effects of false positive or false negative (KQ2)

Timing:

- For clinical outcomes of symptom relief: 1-2 days minimum (KQ1)
- Early in an attack versus later or post-attack (KQ1c)
- For adverse events: immediate

Settings:

- Primary care (outpatient) or acute care settings, preferentially;
- Outpatient rheumatology practices/academic medical centers

## Literature Search Strategies for Identification of Relevant Studies To Answer the Key Questions

The search strategy was designed by the Southern California Evidence-based Practice Center (EPC) reference librarian in collaboration with our local content expert, who has participated in two systematic reviews on gout;19, 20 the search strategy appears in Appendix A. As recommended by the AHRQ EPC Methods Guide for Medical Test Reviews,21 the searches were conducted without filters specific for diagnostic tests; instead we used the terms “gout” combined with the terms for the diagnostic tests. We searched PubMed (1/1/46 to 11/07/14), EMBASE (1/1/72 to 11/07/14), the Cochrane Library (1/1/45 to 11/07/14 for the Cochrane Central Registry of Controlled Trials and 1/1/96 to 11/07/14 for the Cochrane Database of Systematic Reviews), and the Web of Science (from 1/1/80 to 11/07/14); these dates were selected to replicate the searches conducted as the basis for the 2006 EULAR Guidelines on Diagnosis and Management of Gout.22 We also included any relevant studies identified in the searches we conducted for a simultaneous review on management of gout if not already identified in the searches for this review. Finally, we asked the TEP to assess our list of included studies and to provide references for any studies they believe should also be included.

We searched Clinicaltrials.gov and the Web of Science for recently completed studies and unpublished or non-peer-reviewed study findings. Searches were not limited by language of publication: Non-English language studies that met the inclusion/exclusion criteria based on a review of an English-language abstract were screened further in full text if translators could be identified with reasonable effort. We also contacted manufacturers of diagnostic equipment (polarizing microscopes, sonography equipment, DECT, and serum uric acid test kits) were contacted for unpublished data specific to the use of the equipment or tests for gout diagnosis.

An update search was conducted on 11/07/14 after submission of the draft report for peer review.

We transferred the output of the literature searches to DistillerSR™ for screening. Article titles and abstracts identified by the searches were independently screened by two literature reviewers using the predetermined inclusion and exclusion criteria, and those selected by either reviewer were accepted without reconciliation for further, full-text review.

Two reviewers independently conducted full-text review to exclude articles that provided no usable data, reported the same data as another article, or enrolled participants with established gout diagnoses. Disagreements regarding inclusion at the full-text stage were reconciled, with the input of the project lead when necessary.

We identified a small number of relatively recent systematic reviews on various aspects of gout diagnosis; in most cases we used these reviews to identify references we had missed, however if the review was of high quality, addressed a subquestion of interest, and included all the literature on the topic, we included it as a data source after assessing its quality and how it assessed risk of bias and strength of evidence. We also searched the reference lists of included studies for additional titles that appeared to fit our inclusion criteria and screened these articles for inclusion. For studies of apparent interest reported in meeting abstracts (conference proceedings), we searched for peer-reviewed publications of the findings; if findings had not yet been published in a peer reviewed journal, we reserved them and cited them in the last chapter in our discussion of suggestions for future research.

## Data Abstraction and Data Management

Two reviewers independently abstracted study level details from articles accepted for inclusion in DistillerSR. Any disagreements were reconciled with the input of the project leader, Southern California EPC director, or the local subject matter expert if needed. Studies provided by manufacturers or suggested by peer reviewers underwent the same process, as did studies identified in update searches.

## Assessment of Methodological Quality of Individual Studies

Risk of bias (study quality) of individual included studies was assessed independently by two reviewers using the Quality Assessment of Diagnostic Accuracy Studies (QUADAS)-2 tool,23, 24 and assessments were reconciled, with any disagreements mediated by the project lead. We used the Assessing the Quality of Systematic Reviews (AMSTAR) tool to assess the quality of existing systematic reviews that we included;25 AMSTAR assessments were also conducted independently by two reviewers and reconciled.

## Data Synthesis/Analysis

For studies that assessed US, DECT, or another radiographic method, we extracted and reported sensitivity, specificity, positive and negative predictive value, and area under the curve (AUC)/receiver-operating characteristics (ROC) if reported.

We considered studies for meta-analysis if the number of true positives, true negatives, false positives, and false negatives were reported or could be calculated; and if studies were similar enough with respect to outcome measures, participants, and tests, and assessed the validity of an alternative diagnostic method against that of analysis of MSU crystals in synovial fluid. Because the studies we identified precluded pooling, outcomes are described narratively, stratified by test comparisons of interest and study design. All included studies are also described in summary tables.

If any prior SRs were identified that directly addressed a KQ of interest and were deemed of high enough quality to include, we assessed whether any subsequent (or contemporaneous) original studies were sufficiently homogeneous with the review to consider conducting new quantitative synthesis for a particular outcome, based on whether the new study represents a potential pivotal finding in terms of size and effect size and the availability of the needed data. If it was determined that the newer studies could not be combined with the prior SR and could not, themselves, be pooled, we described the newer studies narratively.

## Grading the Strength of the Body of Evidence for Each Key Question

We assessed the overall strength of evidence for each conclusion using guidance suggested by AHRQ for its Effective Health Care Program.26 This method is based on a method developed by the GRADE Working Group. The evidence grade is usually based on five required domains:

- Study limitations: assessed based on the risk-of-bias assessments for all studies that contribute to a conclusion;
- Consistency: because we did not pool studies, we compared the relative sensitivities and specificities;
- Directness: a measure of whether the evidence being assessed reflects a single, direct link between the interventions of interst and the ultimate health outcome under consideration;
- Precision: a measure of the confidence intervals in a pooled analysis, also not assessed in this report;
- Publication bias: also assessed only for studies for which data are pooled

Based on the domains we included, we classified the strength (grade) of evidence as follows:

- High = Further research is unlikely to change our confidence in the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Very low/Insufficient = Any estimate of effect is very uncertain.

## Applicability

To be useful, comparative effectiveness research (or in this case research assessing the comparative validity of a diagnostic test) must use real world interventions and settings to the extent possible. Applicability is a measure of the degree to which participants, intervventions, and outcome measures used in studies included in a review reflect the population and care settings for whom the outcomes are intended. We assessed applicability based on the inclusion and exclusion criteria described in the PICOTS, which included the study population age, sex, health profiles (including comorbidities as well as duration of symptoms and number of affected joints, when relevant), tests, gold standards, study settings, and provider types.27 Thus we would assign higher priority to studies of adult populations being seen in primary/urgent/emergent care settings for first or subsequent episodes of symptoms suggestive of gout than to studies of patients with established gout diagnoses in an academic rheumatology department.

## Peer Review and Public Commentary

A draft version of the report was posted for peer review on 11/4/14 and revised in response to reviewer comments.