# Introduction

## Background

### Condition

Gout is a form of inflammatory arthritis characterized by acute intermittent episodes of synovitis presenting with joint swelling and pain (these episodes are referred to as acute gouty arthritis flares or attacks). The condition may progress to a chronic and persistent condition, with development of tophi (solid deposits of monosodium urate [MSU] crystals in joints, cartilage, tendons, bursae, bone, and soft tissue), a condition called chronic tophaceous gout. There is no clear distinction between acute intermittent and chronic intermittent conditions, whereas the advanced stage of gout is characterized by more persistent joint manifestations and tophi (either clinically evident or hidden within the joint).

Gout is the most common form of inflammatory arthritis, and the prevalence has been increasing. The most recent estimate of prevalence among adults in the United States (U.S.), based on data from the 2007-2008 National Health and Nutrition Examination Survey (NHANES), is3.9 percent (8.3 million individuals), ranging from 2.0 percent in women to 5.9 percent in men,1 an increase over that of previous NHANES data cycles. The rise in the prevalence of gout has paralleled the increase in prevalence of comorbid conditions associated with hyperuricemia (the primary risk factor for gout), including obesity, hypertension, hypertriglyceridemia, hypercholesterolemia, type 2 diabetes, metabolic syndrome, chronic kidney disease, and renal insufficiency. Increased use of medications that increase the risk for developing hyperuricemia (e.g., thiazide diuretics, low-dose aspirin, or their combination) may further explain the increasing prevalence of gout. In a 2013 study that analyzed data from several national surveys administered from 2002 to 2008, the number of ambulatory care visits attributable to gout was estimated to be 7 million visits annually, with 2 million attributable to acute attacks (the rate more than doubled from 2002 to 2008). The total annual ambulatory care (primary care, urgent care, and emergency department) costs associated with gout (visits and medications) were estimated to be $933 million (in 2009 dollars). Drug expenditures accounted for 61 percent of the total costs.2

In addition to gout, the types of inflammatory arthritis include rheumatoid arthritis, septic arthritis, inflammatory episodes of osteoarthritis, and calcium pyrophosphate dehydrate crystal deposition disease (formerly known as pseudogout). Patients with any of these types of arthritis can present with clinically similar signs and symptoms, but the conditions have very different treatments, and incorrect diagnosis can have serious outcomes (for example, missing a septic arthritis can lead to joint damage and septic shock). A major challenge then for effective gout management, particularly in the primary care and urgent/emergent care setting where most gout patients are managed, is distinguishing gout from these other conditions to prevent inappropriate or delayed treatment, which can incur severe complications.

### Etiology of Gout

The driving force behind acute episodes of gout is hyperuricemia (defined as an elevated serum uric acid (more accurately referred to as serum urate, for salt form of uric acid that occurs in serum) concentration greater than 6.8 mg per deciliter [dl] in men and greater than 6.0 in women). Hyperuricemia is most commonly the result of inadequate renal excretion of uric acid or, less commonly, uric acid overproduction (uric acid is a breakdown product of dietary or endogenous purines). Hyperuricemia leads to formation and deposition of MSU crystals, which preferentially deposit in joints, tendons, and bursa spaces. Despite the prevalence of hyperuricemia, for reasons that remain unclear, only a small proportion of individuals with hyperuricemia go on to develop gout. For others, hyperuricemia remains asymptomatic.3 The prevalence of hyperuricemia ranges from 21.2 percent in men to 21.6 percent in women, four- to ten-fold higher than the prevalence of gout.4

The causes of gout are multifactorial, including a combination of genetic, hormonal, metabolic, pharmacologic, comorbid (renal disease), and dietary factors. Family history, advancing age, male sex, or, in women, early menopause have been associated with a higher risk of gout and/or gout flares.5 Dietary risk factors for gout include consumption of purine-rich foods or drinks, including meat, and seafood; and consumption of sugar sweetened soft drinks, alcohol, and foods high in fructose. Dairy foods and coffee have been associated with a lower risk of incident gout and in some cases a lower rate of gout flares. However, the role of diet in the etiology and treatment of gout is a topic of considerable research and will be reviewed in a separate systematic review.

### Diagnostic Strategies

The majority of individuals with gout are initially seen, diagnosed, and treated in primary and urgent care settings. Thus primary care physicians (PCPs) and emergency medicine physicians are the most likely practitioners to see patients with suggestive of an acute attack of gout, but with no prior diagnosis. Such patients may be experiencing a first attack (early-stage gout) or may actually have experienced multiple attacks and have more advanced gout.

Some research has argued the need for laboratory assessment of joint/synovial fluid MSU crystals in the setting of an acute inflammatory arthritis for a definitive diagnosis of gout. MSU crystal analysis has been regarded as the gold standard against which other potential diagnostic methods are measured. However, joint aspiration can be technically difficult and painful to the patient and is often deferred, to be conducted by a specialist (e.g., a rheumatologist or orthopedic surgeon).6 In addition, the accuracy of synovial fluid analysis may be affected by a number of factors (both patient-, practitioner-, and analyst-related).7, 8 A 2009 study found that unguided needle insertion in the toe is often inaccurate.9 At least three studies have found wide variation in the accuracy of assessing synovial fluid crystals (both MSU and calcium pyrophosphate) and white blood cells across hospital laboratories,10-12 which could potentially be due to patient differences, differences in skill levels of the practitioners drawing or analyzing the samples, or differences in sample handling. A 1999 systematic review on the accuracy of MSU crystal analysis in synovial fluid13 concluded that MSU analysis had poor sensitivity, specificity, and reproducibility. And a 2013 systematic review of the accuracy of methods for detecting MSU in synovial fluid concluded that storage of samples at room temperature resulted in a decrease in MSU concentration over time, compared with refrigeration14 but could not draw any conclusions about the role of personnel. In fact, evidence from a 2011 survey of rheumatologists suggests that synovial fluid analysis is underused in the rheumatology setting as well.15

Instead of analyzing MSU crystals in synovial fluid, PCPs and emergency medicine physicians tend to rely on algorithms comprising a combination of clinical signs and symptoms to diagnose an acute episode of gout. These clinical signs and symptoms include rapid development of inflammation and pain, erythema, monoarthritis, response to administration of the drug colchicine, and symptoms in the first metatarsophalangeal (MTP) joint, among others (with synovial fluid culture sometimes used to rule out septic arthritis).

Attempts to standardize and validate such clinical diagnostic algorithms date back to the 1960s.16 Most of these algorithms were not developed for diagnostic purposes but for classification of gout. Concurrent with this review, the American College of Rheumatology (ACR) and the European League against Rheumatism (EULAR) are collaborating to update and evaluate classification criteria for gout. Distinct from diagnostic criteria, classification criteria are intended to ensure the correct identification and staging of patients with a particular disease condition (especially patients in the early stages of the disease) for the purpose of enrollment in studies of disease.17

Therefore, a question of importance is whether any combination of clinical signs and symptoms and laboratory tests accessible in the primary or acute care setting (which we will refer to as a clinical algorithm or clinical diagnostic algorithm) will have good predictive value compared with tests such as joint aspiration and synovial fluid MSU analysis, both to correctly diagnose gout and to rule out other causes of joint inflammation, particularly septic arthritis and calcium pyrophosphate deposition disease among patients presenting with an acute episode of inflammatory arthritis.

Imaging modalities have also been assessed for both diagnosis and classification of gout. These techniques include plain radiographs and newer techniques such as ultrasound and dual-energy computed tomography (DECT), which are just beginning to be used to diagnose gout in some settings.18 Therefore, another question of importance for gout diagnosis is how these newer methods compare with joint aspiration and synovial fluid analysis in their predictive value for the diagnosis of gout and whether they provide any additive value over the use of MSU analysis or clinical signs and symptoms.

The “safety” of tests used to diagnose gout also needs to be considered. Potential safety concerns include acute physical discomfort or infection from joint aspiration and long term effects (e.g., from accumulated radiation exposure). Other concerns are the potential effects of misdiagnosis. These effects could include delay in initiating or failure to initiate appropriate treatment for gout or another disorder or incorrect initiation of treatment for another disorder (e.g., hospitalization and administration of intravenous antibiotics for suspected joint sepsis).

Therefore, we have undertaken a systematic review of studies examining the accuracy and safety of tests used to diagnose gout, including algorithms combining physical signs and symptoms, serum urate, ultrasound, plain radiography, and DECT, compared with synovial fluid MSU analysis. The primary focus of this review is on tests that can be used in the primary care or urgent/emergent care setting for an initial diagnosis of gout. The aim of this review is to help inform clinical decision-making for patients and providers and to improve the quality of care for patients with gout in the primary and acute care setting.

## Scope and Key Questions

### Scope of the Review

The purpose of this review is to assess the evidence on the validity and safety of tests for the purpose of diagnosing gout, including clinical signs and symptoms (individually and in combination as an algorithm), DECT, ultrasound, and other imaging methods, compared with of synovial fluid from involved joints and analysis of MSU crystals using polarized light microscopy. Because evidence also suggests MSU crystal analysis, itself, may not be accurate in all hands or with all patients, the review also assesses the evidence that practitioner type may affect the outcomes of MSU analysis. AHRQ assigned this report to the Southern CA Evidence-based Practice Center (HHSA290201200006I). A protocol for the review was posted on the AHRQ website on July 17, 2014 at: www://effectivehealthcare.ahrq.gov/ehc/products/564/1937/gout-protocol-140716.pdf. The protocol was approved by the AHRQ Center for Evidence and Practice Improvement.

### Key Questions

Figure 1 shows an analytic framework to illustrate the population, interventions, outcomes, and adverse effects that will guide the literature search and synthesis for this project. The framework shows the population of interest, patients with symptoms suggestive of possible gout, undergoing any of a number of potential diagnostic tests, whose validity is the subject of Key Question 1a. Patient level factors that might affect the accuracy of these tests are the topics of Key Questions 1b and 1c. Provider factors that might affect the accuracy of one specific test, MSU analysis, are the topic of Key Question 1d. Key Question 2 assesses potential adverse effects that might be associated with testing: short and long-term harms from the test procedures themselves, and outcomes associated with misdiagnosis. The dotted lines indicate possible outcomes, for example, diagnostic accuracy and adverse effects of testing might affect clinical decision-making, which might in turn affect intermediate and clinical outcomes.

Figure 1 Analytic framework

DECT = dual energy computed tomography; KQ = Key Question; NPV = negative predictive value; PPV = positive predictive value; SUA = serum urate; US = ultrasound

This figure depicts the key questions within the context of the PICOTS described in the previous section. The figure illustrates, first, the participants of interest, adults with suspected gout. The interventions are a set of candidate diagnostic procedures (assessment of clinical signs and symptoms, serum uric acid assay, ultrasound, DECT, plain radiography) for which we will seek studies comparing their diagnostic accuracy to that of joint aspiration and synovial fluid crystal analysis (key question 1a). We will also seek studies that assess the effect of number and type of affected joint, duration of gout flare, and various other patient characteristics (age, sex, comorbidities) on comparative diagnostic accuracy (key questions 1b, c). We will also search for literature that assesses the effect of the type of provider conducting joint aspiration and the type of personnel analyzing the results on the accuracy of synovial fluid analysis and joint aspiration (key question 1d). The outcomes of interest will include measures of test accuracy (e.g., sensitivity and specificity, AUC, PPV, NPV), clinical decisions (such as the decision to order additional testing), intermediate outcomes (i.e., test outcomes such as serum UA levels, presence of MSU crystals in joint aspirate, radiographic evidence), clinical outcomes (e.g., pain, swelling), and harms of the tests (e.g., pain, infection, false positives, or false negatives) (key question 2).

The Key Questions that guided this review are based on questions posed by the American College of Physicians. These questions underwent revision based on input from a group of key informants, public comments, and input from a Technical Expert Panel (TEP).

Key Question 1.

a. What is the accuracy of clinical signs and symptoms and other diagnostic tests (such as serum uric acid, ultrasound, CT scan, DECT, and plain x-ray), alone or in combination, compared with^a^ synovial fluid analysis in the diagnosis of acute gouty arthritis, and how does the accuracy affect clinical decisionmaking, clinical outcomes and complications, and patient centered outcomes?
  a Using monosodium urate crystal analysis of synovial fluid as the reference standard.
b. How does the diagnostic accuracy of clinical signs and symptoms and other tests vary by affected joint site and number of joints?
c. Does the accuracy of diagnostic tests for gout vary by duration of symptoms (i.e., time from the beginning of a flare)?
d. Does the accuracy of synovial fluid aspiration and crystal analysis differ by i) the type of practitioner who is performing the aspiration and ii) the type of practitioner who is performing the crystal analysis?

Key Question 2. What are the adverse effects (including pain, infection at the aspiration site, radiation exposure) or harms (related to false positives, false negatives, indeterminate results) associated with tests used to diagnose gout?

## Organization of This Report

The remainder of this report presents the methods used to conduct the literature searches, data abstraction, and analysis for this review; the results of the literature searches, organized by Key Question; the conclusions; and a discussion of the findings within the context of what is already known, the limitations of the review and the literature, as well as suggestions for future research.